# Background

## Context

This Future Research Needs (FRN) report is based on a draft Agency for Healthcare Research and Quality comparative effectiveness review titled Interventions for Adolescents and Young Adults with autism spectrum disorder. The purpose of the review was to synthesize recent research focused on interventions for adolescents and young adults between the ages of 13 and 30 with autism spectrum disorder (ASD; autistic disorder, Asperger’s syndrome, pervasive developmental disorder–not otherwise specified). We addressed questions related to: the effectiveness of therapies targeting core symptoms of ASD (impairments in communication, social interaction, and behavior); common medical or mental health comorbidities, including associated symptoms such as irritability; the process of transitioning to adulthood; and family outcomes. The draft review is based on literature searches that were executed between September 2010 and December 2011. The publication of the final review is expected for August 2012.

The Key Questions (KQs) for the review were:

- KQ1: Among adolescents and young adults with ASD, what are the effects of available interventions on the core symptoms of ASD?
- KQ2: Among adolescents and young adults with ASD, what are the effects of available interventions on common medical and mental health comorbidities (e.g., epilepsy, sleep disorders, motor impairments, obesity, depression, anxiety, acute and episodic aggression, attention deficit hyperactivity disorder, etc.)?
- KQ3: Among adolescents and young adults with ASD, what are the effects of available interventions on functional behavior, attainment of goals toward independence, educational attainment, occupational/vocational attainment, life satisfaction, access to health and other services, legal outcomes, and social outcomes?
- KQ4: Among adolescents and young adults with ASD, what is the effectiveness of interventions designed to support the transitioning process, specifically to affect attainment of goals toward independence, educational attainment, occupational/vocational attainment, life satisfaction, access to health and other services, legal outcomes, and social outcomes?
- KQ5: Among adolescents and young adults with ASD, what harms are associated with available interventions? (Harms are defined by the Effective Health Care Program as all possible adverse consequences of an intervention, including adverse events.)
- KQ6: What are the effects of interventions on family outcomes?

### Importance of the Subject

ASD (autistic disorder, Asperger syndrome, or pervasive developmental disorder–not otherwise specified) has an estimated prevalence of one in 88 children.1 More than 55,000 individuals between the ages of 15 and 17 in the United States likely have ASD.2 The diagnosis for ASD is behaviorally based, relying on documented core impairments in social interaction and communication, as well as restricted and repetitive behavior. For some individuals, core symptoms of ASD (impairments in communication, social interaction, and behavior) may improve to some degree with intervention and over time.3–6

As children transition to adolescence and young adulthood, developmentally appropriate interventions targeting core deficits may continue, but the focus of treatment often shifts toward promoting adaptive behaviors that can facilitate and enhance independent functioning.7 Investigators have noted that less research on therapies for adolescents and young adults exists than for younger children8 and that such research is increasingly critical as the prevalence of ASD continues to grow and as children with ASD diagnoses reach adolescence.

The AHRQ review grew out of a recognition that care for adolescents and young adults with ASD varies greatly across care providers and that clinicians and families must make important health care decisions with little guidance or knowledge. Similarly, lawmakers struggle with making the best decisions about policy and funding due to lack of an adequate knowledge base regarding the most effective treatments. The lack of services available to help young adults with ASD transition to greater independence has been noted by researchers for a number of years and is increasingly a topic in the lay media.9

There is also evidence to suggest that improvements in symptoms and in problem behaviors may diminish after youth with ASD leave high school.10 This change in improvement is likely due, at least in part, to the termination of services received through the secondary school system upon high school exit, as well as the lack of adult services and long waiting lists for many services.10, 11 Despite a growing population of adolescents and young adults who have diagnoses of an ASD and the need for effective intervention across the lifespan, very little research is available to guide treatment of adolescents and young adults with ASD.

### Findings of the Comparative Effectiveness Review

The authors of the draft review examined the effectiveness of therapies intended to improve the core symptoms of ASD, promote independent functioning, facilitate transitions, and assist families of individuals with ASD. The draft review identified 32 studies meeting prespecified inclusion/exclusion criteria. Most were poor quality, five were fair quality, and none was good quality.

For KQ1, 14 studies targeted core symptoms (impairments in communication, social interaction, or behavior) of ASD. Ten studies addressed functional behavior/independent living skills (KQ3). Nine studies addressed medical interventions (KQ2), and only medical studies addressed harms (KQ5). One study addressed the transition process (KQ4) and two studies addressed family outcomes (KQ6).

The studies in KQ2 examined the effects of interventions on comorbid medical or mental health conditions (e.g., epilepsy, sleep disorders, motor impairments, obesity, depression, anxiety, acute and episodic aggression, attention deficit hyperactivity disorder, etc.). Most studies assessed the use of medications to address challenging behaviors (i.e., defiance, aggression, or self-injury) in adolescents and young adults. Evidence remains insufficient regarding what works for managing challenging behaviors in adolescents and young adults.

One study addressed interventions targeting the transition process (KQ4). In vocational research, studies are needed that illuminate which aspects of multifaceted supported employment programs have the greatest impact. Individual studies also suggested that vocational programs may increase employment success, but the studies were small. Given the number of individuals affected by ASD, there is a dramatic lack of evidence on best approaches to therapies for adolescents and young adults with these conditions.

Harms of interventions (KQ5) were only discussed in studies of medical approaches. Two studies addressing KQ6 assessed effects of an intervention on family outcomes. More research over a broader time frame with more clearly defined populations is critical for helping individuals with ASD transition to greater independence. Foundational research is necessary to understand the goals of individuals with autism and their families as future research studies are planned. Similarly, little research addresses the effects of family and caregiver interactions and characteristics on the responses of individuals’ with ASD to interventions.

Better outcome measures are needed to allow assessment of a broader range of symptoms, particularly in individuals who may be higher functioning. Despite increasing numbers of adolescents transitioning into adulthood, no area of research provides sufficient strength of evidence for the impact of specific intervention strategies in terms of improving important outcomes for specific groups of individuals with ASD. Overall, there is a dearth of evidence in all areas of care for adolescents and young adults with ASD, and it is urgent that more rigorous studies be developed and conducted.

### Objectives

The purpose of this FRN project was to identify research gaps and prioritize the identified research needs related to interventions for adolescents and young adult with ASD to help inform ongoing research and assist individuals, families, and clinicians in making health care decisions.

## Evidence Gaps

The Vanderbilt Evidence-based Practice Center (EPC) identified significant gaps in the research literature addressing adolescents and young adults with ASD including:

- An overall paucity of research, especially addressing questions related to transitioning to independence (total studies included in the review = 32, with none of good quality)
- Small sample sizes, with studies typically including fewer than 50 individuals, many with co-occurring intellectual disability
- Very little long-term followup with only three studies reporting outcomes past 12 months
- Lack of randomized controlled trials in all categories of intervention, but especially so in medical interventions, where substantial adverse events may be associated with medication use in adolescence.
- Multiple interventions and outcomes studies, with little replication of studies using the same interventions or outcomes
- Gaps in reporting characteristics of the study populations
- Inconsistent reporting of methodology
- Inconsistent or absent reporting of harms

Specifically, in KQ1, further research is needed to understand the impact of behavioral interventions and how these interventions generalize to real-world impact and outcome for individuals with ASD. Allied health studies are also needed to understand best approaches to fostering independent living skills, as well as evaluate how improvements in motor skills may affect communication and other domains. In KQ2, additional data are needed on medical comorbidities in adolescents with ASD. Population studies and increased use of standardized age groupings would facilitate comparisons of effectiveness within medical intervention categories as well as with nonmedical therapies. We found in KQ4 that no studies provided adequate information on longer term outcomes, and particularly on outcomes related to achieving goals for independence and quality of life. Foundational research is needed to identify and validate outcome measures in the adolescent and young adult population with ASD. Future research is also necessary to understand how individuals’ expression of ASD symptoms and the severity of symptoms may affect treatment over the lifespan. For KQ5, data about harms were only available from medical studies.

We added indications for these preliminary gaps to the analytic framework from the full report. The analytic framework illustrates the KQs, population, interventions, comparators, outcomes, timeframes, and settings (PICOTS), and identified research gaps below in Figure 1.

Figure 1 Analytic framework depicting relationships between KQs, populations, interventions, outcomes, and components of evidence gaps

The analytic framework depicts the relationships between the Key Questions, populations, interventions, outcomes, and components of evidence gaps and outlines the path by which individuals 13–30 years old with an autism spectrum disorder and family members of such individuals make and modify treatment choices. Choice of therapeutic modalities may target intermediate outcomes including changes in communication skills, academic skill development, or social skills. Interventions lead to long-term outcomes such as adaptive independence, academic and occupational/vocational attainment, and psychological well-being. Family outcomes such as parent distress may also be targeted by interventions that lead to intermediate or long-term outcomes. Interventions may be associated with harms/adverse effects. Numbers in circles within the diagram indicate the placement of the key questions in relation to the treatment process. Finally, research gaps including interventions to facilitate transition to adulthood and adaptive independence, harms of non-medical approaches, and interventions addressing family outcomes are located within the diagram in relation to the treatment process.