# Second-Round Prioritization Survey Results

Final prioritization results over all modified EHC criteria

Research Question | Total points combining all criteria | Total overall ranking
Q8 What is the effectiveness of available interventions for treating behavioral issues including sudden aggression and catatonia during transition years in adolescents and young adults with ASD? | 148 | High
Q13 What is the effectiveness of early intervention programs to improve functional behavior in adolescents and young adults with ASD? | 147 | High
Q1 What is the effectiveness of available transition programs (e.g., work readiness programs, community programs, vocational programs, private ABA schools, Cognitive Behavior Therapy (CBT) programs, social skills training and programs, person-centered planning) in ASD? | 146 | High
Q10 What is the effectiveness of paradigms and combinations of paradigms currently used in community based programs for adolescents and young adults with ASD? | 138 | High
Q2 What is the impact of common transition programs across individual, familial, and more broadly defined outcomes? | 138 | High
Q6 What measurable psychiatric and medical comorbidities predict less successful transition from supportive educational settings as well as impact quality of life metrics? | 137 | High
Q4 What measurable characteristics (individual, familial, system) predict successful transition from supportive educational settings? | 135 | Middle
Q9 What are the measurable characteristics that determine a satisfying quality of life for adolescents and young adults with ASD? | 133 | Middle
Q11 How can the trajectory of comorbidities in adolescents and young adults with ASD be measured over the lifespan? | 132 | Middle
Q7 What is the impact of common behavioral interventions (manualized CBT and familial treatment paradigms on anxiety/depression) treating psychiatric comorbidities in non-ASD samples in combination/comparison with pharmacological paradigms aimed at treating comorbidities? | 128 | Low
Q5 What is the validity of best available existing psychiatric comorbidity measurements across adolescents and young adults with ASD? | 124 | Low
Q12 What are appropriately sensitive metrics of quality of life, functional outcome, and how does that overlay with the heterogeneous range of characteristics of individuals, families, and systems in ASD? | 121 | Low
Q3 What is the effectiveness of interventions designed to support goals toward life satisfaction for adolescents and young adults with ASD and family members? | 120 | Low

Final prioritization results for each modified EHC criteria and stakeholder votes

Q8 What is the effectiveness of available interventions for treating behavioral issues including sudden aggression and catatonia during transition years in adolescents and young adults with ASD?
Potential for significant health impact. | Potential to reduce variation in clinical practices. | Potential for significant economic impact. | Potential risk from inaction. | Potential to address inequities. | Potential for new knowledge. | Total Q8
5 | 5 | 5 | 5 | 5 | 5 | 30
5 | 4 | 4 | 5 | 4 | 5 | 27
5 | 5 | 5 | 5 | 5 | 5 | 30
3 | 3 | 3 | 3 | 3 | 4 | 19
4 | 3 | 4 | 3 | 4 | 4 | 22
4 | 4 | 3 | 3 | 3 | 3 | 20
26 | 24 | 24 | 24 | 24 | 26 | 148
Q13 What is the effectiveness of early intervention programs to improve functional behavior in adolescents and young adults with ASD?
Potential for significant health impact. | Potential to reduce variation in clinical practices. | Potential for significant economic impact. | Potential risk from inaction. | Potential to address inequities. | Potential for new knowledge. | Total Q13
4 | 4 | 4 | 3 | 4 | 4 | 23
5 | 4 | 5 | 4 | 4 | 5 | 27
5 | 5 | 5 | 5 | 5 | 5 | 30
3 | 3 | 3 | 3 | 3 | 3 | 18
4 | 4 | 4 | 4 | 4 | 4 | 24
5 | 4 | 4 | 4 | 3 | 5 | 25
26 | 24 | 25 | 23 | 23 | 26 | 147
Q1 What is the effectiveness of available transition programs (e.g., work readiness programs, community programs, vocational programs, private ABA schools, Cognitive Behavior Therapy (CBT) programs, social skills training and programs, person-centered planning) in ASD?
Potential for significant health impact. | Potential to reduce variation in clinical practices. | Potential for significant economic impact. | Potential risk from inaction. | Potential to address inequities. | Potential for new knowledge. | Total Q1
4 | 4 | 4 | 4 | 4 | 5 | 25
5 | 3 | 5 | 5 | 4 | 5 | 27
5 | 5 | 4 | | 3 | 3 | 20
4 | 3 | 5 | 4 | 4 | 4 | 24
5 | 4 | 4 | 5 | 4 | 5 | 27
4 | 3 | 5 | 4 | 3 | 4 | 23
27 | 22 | 27 | 22 | 22 | 26 | 146
Q10 What is the effectiveness of paradigms and combinations of paradigms currently used in community based programs for adolescents and young adults with ASD?
Potential for significant health impact. | Potential to reduce variation in clinical practices. | Potential for significant economic impact. | Potential risk from inaction. | Potential to address inequities. | Potential for new knowledge. | Total Q10
3 | 3 | 3 | 3 | 3 | 3 | 18
5 | 4 | 4 | 4 | 5 | 5 | 27
5 | 5 | 5 | 5 | 5 | 5 | 30
4 | 4 | 4 | 3 | 3 | 3 | 21
4 | 3 | 4 | 4 | 3 | 4 | 22
4 | 3 | 4 | 3 | 3 | 3 | 20
25 | 22 | 24 | 22 | 22 | 23 | 138
Q2 What is the impact of common transition programs across individual, familial, and more broadly defined outcomes?
Potential for significant health impact. | Potential to reduce variation in clinical practices. | Potential for significant economic impact. | Potential risk from inaction. | Potential to address inequities. | Potential for new knowledge. | Total Q2
4 | 4 | 4 | 4 | 4 | 5 | 25
3 | 3 | 4 | 4 | 3 | 3 | 20
5 | 4 | 2 | 2 | 4 | 5 | 22
4 | 3 | 5 | | 4 | 4 | 20
5 | 4 | 5 | 4 | 4 | 3 | 25
5 | 4 | 5 | 4 | 3 | 5 | 26
26 | 22 | 25 | 18 | 22 | 25 | 138
Q6 What measurable psychiatric and medical comorbidities predict less successful transition from supportive educational settings as well as impact quality of life metrics?
Potential for significant health impact. | Potential to reduce variation in clinical practices. | Potential for significant economic impact. | Potential risk from inaction. | Potential to address inequities. | Potential for new knowledge. | Total Q6
5 | 4 | 4 | 5 | 5 | 5 | 28
5 | 4 | 4 | 5 | 4 | 5 | 27
4 | 4 | 5 | 4 | 3 | 4 | 24
3 | 3 | 4 | | 3 | 3 | 16
5 | 4 | 4 | 3 | 3 | 5 | 24
3 | 3 | 3 | 3 | 3 | 3 | 18
25 | 22 | 24 | 20 | 21 | 25 | 137
Q4 What measurable characteristics (individual, familial, system) predict successful transition from supportive educational settings?
Potential for significant health impact. | Potential to reduce variation in clinical practices. | Potential for significant economic impact. | Potential risk from inaction. | Potential to address inequities. | Potential for new knowledge. | Total Q4
4 | 4 | 3 | 3 | 4 | 4 | 22
4 | 3 | 4 | 2 | 4 | 5 | 22
5 | 5 | 5 | 5 | 5 | 5 | 30
3 | 3 | 4 | 3 | 3 | 4 | 20
4 | 4 | 4 | 3 | 3 | 5 | 23
4 | 3 | 3 | 3 | 2 | 3 | 18
24 | 22 | 23 | 19 | 21 | 26 | 135
Q9 What are the measurable characteristics that determine a satisfying quality of life for adolescents and young adults with ASD?
Potential for significant health impact. | Potential to reduce variation in clinical practices. | Potential for significant economic impact. | Potential risk from inaction. | Potential to address inequities. | Potential for new knowledge. | Total Q9
3 | 3 | 3 | 3 | 3 | 3 | 18
4 | 3 | 3 | 4 | 3 | 4 | 21
5 | 5 | 5 | 5 | 5 | 5 | 30
4 | 3 | 4 | 3 | 4 | 4 | 22
3 | 3 | 4 | 3 | 4 | 3 | 20
4 | 3 | 4 | 4 | 3 | 4 | 22
23 | 20 | 23 | 22 | 22 | 23 | 133
Q11 How can the trajectory of comorbidities in adolescents and young adults with ASD be measured over the lifespan?
Potential for significant health impact. | Potential to reduce variation in clinical practices. | Potential for significant economic impact. | Potential risk from inaction. | Potential to address inequities. | Potential for new knowledge. | Total Q11
3 | 3 | 2 | 2 | 2 | 2 | 14
5 | 4 | 4 | 4 | 4 | 5 | 26
5 | 4 | 5 | 5 | 5 | 5 | 29
4 | 3 | 4 | 3 | 4 | 4 | 22
3 | 4 | 4 | 4 | 4 | 5 | 24
4 | 2 | 2 | 3 | 2 | 4 | 17
24 | 20 | 21 | 21 | 21 | 25 | 132
Q7 What is the impact of common behavioral interventions (manualized CBT and familial treatment paradigms on anxiety/depression) treating psychiatric comorbidities in non-ASD samples in combination/comparison with pharmacological paradigms aimed at treating comorbidities?
Potential for significant health impact. | Potential to reduce variation in clinical practices. | Potential for significant economic impact. | Potential risk from inaction. | Potential to address inequities. | Potential for new knowledge. | Total Q7
4 | 5 | 4 | 4 | 4 | 4 | 25
5 | 4 | 4 | 4 | 4 | 5 | 26
1 | 1 | 1 | 1 | 1 | 1 | 6
4 | 3 | 4 | 3 | 4 | 4 | 22
5 | 5 | 4 | 5 | 3 | 4 | 26
5 | 4 | 4 | 3 | 3 | 4 | 23
24 | 22 | 21 | 20 | 19 | 22 | 128
Q5 What is the validity of best available existing psychiatric comorbidity measurements across adolescents and young adults with ASD?
Potential for significant health impact. | Potential to reduce variation in clinical practices. | Potential for significant economic impact. | Potential risk from inaction. | Potential to address inequities. | Potential for new knowledge. | Total Q5
4 | 4 | 4 | 3 | 3 | 4 | 22
4 | 4 | 3 | 4 | 4 | 5 | 24
2 | 2 | 2 | 1 | 2 | 1 | 10
3 | 4 | 4 | 3 | 3 | 4 | 21
5 | 4 | 4 | 3 | 3 | 5 | 24
4 | 4 | 4 | 4 | 3 | 4 | 23
22 | 22 | 21 | 18 | 18 | 23 | 124
Q12 What are appropriately sensitive metrics of quality of life, functional outcome, and how does that overlay with the heterogeneous range of characteristics of individuals, families, and systems in ASD?
Potential for significant health impact. | Potential to reduce variation in clinical practices. | Potential for significant economic impact. | Potential risk from inaction. | Potential to address inequities. | Potential for new knowledge. | Total Q12
2 | 2 | 2 | 2 | 2 | | 10
4 | 3 | 3 | 4 | 4 | 5 | 23
4 | 4 | 4 | 4 | 4 | 4 | 24
4 | 3 | 4 | 3 | 3 | 4 | 21
3 | 3 | 3 | 3 | 3 | 4 | 19
5 | 3 | 4 | 4 | 3 | 5 | 24
22 | 18 | 20 | 20 | 19 | 22 | 121
Q3 What is the effectiveness of interventions designed to support goals toward life satisfaction for adolescents and young adults with ASD and family members?
Potential for significant health impact. | Potential to reduce variation in clinical practices. | Potential for significant economic impact. | Potential risk from inaction. | Potential to address inequities. | Potential for new knowledge. | Total Q3
3 | 3 | 3 | 3 | 3 | 3 | 18
4 | 3 | 3 | 3 | 3 | 4 | 20
3 | 3 | 1 | 1 | 4 | 3 | 15
4 | 3 | 4 | 3 | 3 | 4 | 21
4 | 3 | 3 | 4 | 3 | 3 | 20
5 | 3 | 4 | 5 | 4 | 5 | 26
23 | 18 | 18 | 19 | 20 | 22 | 120