# Second Web-Based Prioritization Survey

This figure depicts the second Web-based prioritization survey exploring future research related to intervention for adolescents and young adults with Autism Spectrum Disorders. In this final survey, we asked stakeholders to rank the thirteen potential areas of research (1 [lowest] to 5 [highest]) on six AHRQ Effective Health Care Program Topics prioritization criteria. The criteria include: potential for significant health impact; potential to reduce variation in clinical practices; potential for significant economic impact; potential risk from inaction; potential to address inequities; and potential for new knowledge. The questions and results from the survey are listed in Appendix H.