# First-Round Prioritization Survey Results

## Prioritization Survey Round 1: List of Research Questions with Total Votes Allotted

Upper tier research questions (receiving 5 or more stars)

No. | Research Question | Total # of stars | # of stakeholders contributed
17 | What is the effectiveness of available transition programs (e.g., work readiness programs, community programs, vocational programs, private ABA schools, Cognitive Behavior Therapy (CBT) programs, social skills training and programs, person-centered planning) in ASD? | 10 | 5
21 | What is the impact on the most common transition programs across individual, familial, and more broadly defined outcomes? | 8 | 5
22 | What is the effectiveness of interventions designed to support goals toward life satisfaction for adolescents and young adults with ASD and family members? | 7 | 5
1 &16 | What measurable characteristics (individual, familial, system) predict successful transition from supportive educational settings? | 3^*^ & 4^*^ | 4
8 | What is the validity of best available existing psychiatric comorbidity measurements across adolescents and young adults with ASD? | 6 | 3
9 | What measurable psychiatric and medical comorbidities predict less successful transition from supportive educational settings as well as impact quality of life metrics? | 6 | 4
10 | What is the impact of common behavioral interventions (manualized CBT and familial treatment paradigms on anxiety/depression) treating psychiatric comorbidities in non-ASD samples in combination/comparison with pharmacological paradigms aimed at treating comorbidities? | 6 | 4
15 | What is the effectiveness of available interventions for treating behavioral issues including sudden aggression and catatonia during transition years in adolescents and young adults with ASD? | 6 | 4
19 | What are the measurable characteristics that determine a satisfying quality of life for adolescents and young adults with ASD? | 6 | 4
7 | What is the effectiveness of paradigms and combinations of paradigms currently used in community based programs for adolescents and young adults with ASD? | 5 | 3
13 | How can the trajectory of comorbidities in adolescents and young adults with ASD be measured over the lifespan? | 5 | 3
18 | What are appropriately sensitive metrics of quality of life, functional outcome, and how does that overlay with the heterogeneous range of characteristics of individuals, families, and systems in ASD? | 5 | 4
20 | What is the effectiveness of early intervention programs to improve functional behavior in adolescents and young adults with ASD? | 5 | 4

* KQ1_1 and KQ3_1 were the same question. There was no overlap on stakeholder votes, combined total from both questions

Lower tier research questions (receiving 4 or fewer stars)

No. | Research question | Total # of stars | # of stakeholders contributed
2 | What is the validity of best available quality of life measurements across adolescents and young adults with ASD?; - How do families define transition?; - How do individuals affected by ASD define transition (individualistic constructs of meaningful engagement and productivity)?; - Efficacy studies aimed at promoting novel and relative definitions of meaningful social engagement (i.e., community engagement, social networks, peer-mediated, adult mentored, club/activity). | 4 | 3
4 | What is the impact of augmentative communication and novel technological paradigms for individuals with severe communication impairments at specific developmental target ranges (e.g., nonverbal, co-morbid intellectual disability, adolescents)? | 4 | 3
14 | What is the impact of comorbidities on family life over the lifespan? | 4 | 3
24 | What is the impact of interventions on stress levels for family members and adolescents and young adults with ASD? | 3 | 3
3 | What is the impact of common social and behavioral interventions in combination/comparison with pharmacological paradigms aimed at enhanced social learning on core symptoms? | 2 | 2
6 | What is the effectiveness of interventions implemented in the community compared to the research setting among adolescents and young adults with ASD? | 2 | 2
11 | What is the validity of standard measurements for assessing mental health in adolescents and young adults with ASD? | 2 | 2
12 | What is the utility of measures developed for nonautistic individuals with mental health disorders in adolescents and young adults with ASD with mental health comorbidities? | 2 | 2
5 | What is the effectiveness of comprehensive and intensive treatment approaches (specific educational, residential, intensive work programs) in adolescents with ASD for ameliorating core symptoms? | 1 | 1
23 | Explicit inclusion markers of broadly defined harm, adverse event, distress/impact across defined intervention studies above. | 1 | 1
26 | To what extent does participation in services and potential dependency on services lead to declining ability to function independently in adolescents and young adults with ASD? | 1 | 1
25 | What is the effectiveness of systems level interventions specific to the legal system in managing adolescents and young adults with ASD? | 0 | 0
27 | Explicit inclusion markers of broadly defined measures of family impact in studies above. | 0 | 0