# First Web-Based Prioritization Survey

This figure depicts the first Web-based prioritization survey for future research needs: interventions for adolescents and young adults with Autism Spectrum Disorders. The prioritization survey consists of 27 potential systematic research questions. For the first round prioritization, we asked stakeholders to allot stars to each research question. The more stars (up to 5 per question) added to any question, the higher the item was ranked in comparison with the other questions on the survey. Each stakeholder was alloted a total of 18 stars to distribute between 27 questions. The prioritization survey closed June 4, 2012. The questions and results from the survey are listed in Appendix F.