# Current and Ongoing Research

I. ClinicalTrials.gov – 3/13/2012

autism OR autistic OR asperger* OR pervasive development* OR PDD-NOS | Interventional Studies

272 results

Omitted 161 due to being exclusively outside the 13–30 year age range, not having a therapeutic component, or not being a study of autism, Asperger syndrome, or PDD-NOS.

Retained 72 drug therapy studies, 14 behavioral studies, 9 studies on dietary or supplement-based interventions, 3 studies in complementary and alternative medicine (all on acupuncture), and 13 miscellaneous studies. The drug therapy studies included: atomoxetine for ADHD symptoms, antipsychotics including aripiprazole, risperidone, and ziprasidone, along with guanfacine, galantamine, oxytocin, fluoxetine, valproate, divalproex sodium, oxcarbazepine, arbaclofen, baclofen, methylphenidate, metformin, riluzole, buspirone, paliperidone, memantine, citalopram, and other drugs (including investigational drugs). Behavioral and educational interventions include cognitive behavioral therapy, social skills training, parent education, and other approaches. Dietary/supplement approaches included gluten-free diets, broccoli sprout extract, omega-3 fatty acids, and other interventions. There were also several other interventions under investigation, including neurofeedback, hyperbaric oxygen therapy, hippotherapy, and other approaches.

II. CenterWatch – 3/15/2012

Browsed to Clinical Trials: Autism - http://www.centerwatch.com/clinical-trials/listings/condition/612/autism

10 unique trials were identified; 4 of these are omitted due to be duplicates of clinicaltrials.gov results and/or being the inappropriate age group. Of the 6 retained results, drug therapy approaches (3) included arbaclofen for social withdrawal, an unnamed drug for behavioral problems, and an unnamed investigational medicine. Two additional studies should likely be omitted as assessment only (IQ tests, sensory integration). The final retained study did not provide details of the intervention.

III. NIH RePORTER – 3/20/2012

Searched Advanced Text for (autism OR autistic OR asperger OR PDD-NOS) AND (teen OR adolescent OR “young adult” OR “young adults”) limited to Protect Title, Project Abstracts, and Project Terms.

117 results

Many of these results are observational, researcher training, basic science, genetic, or animal studies or otherwise not therapy trials in desired population. Only 4 of the results appeared to be therapy trials in the relevant population; these addressed language learning skills, cognitive enhancement therapy, school/community-based intervention for social skills, and an employment skills program.

IV. Autism Clinical Trials Network (at Autism Speaks) – 3/20/2012

http://www.autismspeaks.org/science/resources-programs/autism-clinical-trials-network

Lists trials on memantine (not enrolling, age groups not described) and on fluoxetine (completed enrollment, ages 5–17 years)

V. Autism Speaks (autismspeaks.org) – 3/20/2012

RFA, Treatment Research Grants: Full and Pilot Level, 2012 Cycle

Includes the following treatment related research priorities (along with environmental risk factors, biomarkers, and dissemination/implementation): “improve quality of life through more effective medicines, behavioral interventions, and technologies;” treatment of underserved/understudied populations, specifically including nonverbal persons with AS< ethnically-diverse and/or low resource communities; adults; those with medical comorbidities.

VI. Autism Speaks Grant Search – 3/20/2012 - http://www.autismspeaks.org/about-us/grant-search/results/taxonomy%3A10006

156 grants, 2006-present (18 from 2006, 28 from 2007, 20 from 2008, 6 from 2009, 23 from 2010, 60 from 2011, 1 from 2012)

Interventions include or address pivotal response treatment, bilingual language exposure, virtual reality, melatonin, mematine, social skills interventions, play, joint attention, sensory integration, mecamylamine, complementary and alternative medicine approaches including acupuncture and acupressure, verbal skills, risperidone, cholesterol, robotics, cognitive-behavioral group treatment, parent training, noise cancelation, and other approaches. However, it is not readily apparent whether the appropriate age group is addressed from the basic records here, and many studies included among the 156 results may be basic science, animal studies, or other approaches that are not of interest.

VII. AHRQ – Grants On-Line Database - http://gold.ahrq.gov/projectsearch/grant_search.jsp - 3/21/2012

Search Criteria - Abstract Text contains: autism, autistic, asperger, PDD-NOS Retrieved 4 results. Three of these apply to a computer-based decision support system for providers of autism care and effects on patient care; the fourth is related to dissemination of relevant AHRQ CER products.