# Prioritization Criteria Methods (PiCMe)

Table B-1 Modified EHC Criteria based on Prioritization Criteria Methods (PiCMe)

Potential for significant health impact on the current and future health status of people with respect to burden of the disease and health outcomes: mortality, morbidity, and quality of life.
Potential to reduce important inappropriate (or unexplained) variation in clinical practices known to relate to quality of care.
Potential to resolve controversy or dilemmas in what constitutes appropriate health care. Potential to improve decision-making for patient or provider, by decreasing uncertainty.
Potential for significant (nontrivial) economic impact related to the costs of health service, to reduce unnecessary or excessive costs; to reduce high costs due to high volume use, to reduce high costs due to high unit cost or aggregate cost. Costs may impact consumers, patients, health care systems, or payers.
Potential risk from inaction: Unintended harms from lack of prioritization of proposed research, opportunity cost of inaction.
Potential to address health inequities, vulnerable, diverse populations (including issues for patient subgroups), potential to reduce health inequities.
Potential for new knowledge: Research would not be redundant, question not sufficiently researched, including completed and in-process research, utility of available evidence limited by changes in practice, e.g., disease detection or evolution in technology.