# Nonresearch Recommendations/Needs Identified During the Snowball Survey

Nonresearch recommendations/needs identified in CER and by stakeholders

1 | Need for pragmatic trials that look at interventions as they actually occur.
2 | Need to develop studies that are adequately powered and designed to capture the moderator information.
3 | Need measures to define quality of life beyond good or poor outcomes, work status, relationship status, and how to measure quality of life across the research base.
4 | Need tools/measurements to assess harms throughout the intervention regarding patient satisfaction (e.g. happiness, quality of life measures) and stress.
5 | Need to develop studies that look at prevention of wandering and elopement during transitional years in adolescent and young adults with ASD
6 | Systems level measures need to be developed to measure outcomes of adolescents and young adults with ASD, including family outcomes. Outcomes need to include the family as a usual element of studies of adolescents and young adults with ASD.
7 | Need to compare caretaker burden in other disease conditions (i.e., Alzheimer’s) and the effect it has on family members, spouse and children, and other relatives.

ASD = Autism Spectrum Disorders