# Acknowledgments

The Vanderbilt Evidence-based Practice Center would like to gratefully acknowledge the thoughtful input of the stakeholders who participated in this project. We would like to express gratitude to Vanderbilt EPC staff. We also would like to thank the University of North Carolina at Chapel Hill Cecil G. Sheps Center for Health Services Research, for use of their online prioritization survey software, and Vanderbilt Institute for Clinical and Translational Research for the use of their REDCap^TM^ survey software.