# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
ASD: Autism Spectrum Disorders
CBT: Cognitive behavior therapy
CER: Comparative Effectiveness Review
EHC: Effective Health Care
EPCs: Evidence-based Practice Centers
FRN: Future Research Need
KQ: Key Question
PiCMe: Prioritization Criteria Methods
PICOTS: Population, interventions, comparators, outcomes, timeframes, and settings
RCT: Randomized controlled trial
TOO: Task Order Officer