# Results

## Contribution of Ongoing Studies and Recent Publications

We did not find that any research gap was adequately addressed by recently completed studies. (See Appendix B) A few studies underway, specifically the FAITH and HEALTH trials have incorporated more complete conceptual models, are using validated outcomes assessment tools, and are collecting data to help understand the potential impact of factors such as the quality of surgical technique on patient outcomes.

## Recommended Research

Stakeholders identified fundamental outcomes measurement issues that require resolution among orthopaedic surgeons and other researchers to meaningfully advance hip fracture outcomes knowledge. The mechanism to resolve these interdisciplinary outcomes issues, recommended by the Minnesota EPC and endorsed by the stakeholders, was a consensus conference.

Table 2 provides a summary of stakeholder rankings for consensus conference topics. All items related to measurement were rated as moderately (scores in the 6 to 7 range) to highly important (scores in the 8 to 9 range). High priority and high importance was placed on a broad set of measurement consistency issues that are more generally accepted as important to researchers across disciplines. Such items included priority outcomes to be reported across studies, and establishing definitions and the recommended use of pertinent predictor variables. Items that received lower priority scores are largely items which are associated with one specific discipline or another, be it a surgical view, a rehabilitation view, or an epidemiological view. The trending toward wider standard deviations among lower-ranked conference topics also highlights the wider variation in the stakeholder responses to these items.

Table 2 Stakeholder ranking of consensus conference topics

Consensus Conference Item | Rank | Importance Mean (SD)
How important is it to have established, consistent reporting of post-treatment outcomes (function, pain, living situation, mortality, quality of life) | 1 | 9.2 (1.3)
How important is it to have established, consistent definitions of the types of fracture | 2 | 8.7 (1.7)
How important is it to have a tool box of validated outcomes measures? | 3 | 8.5 (1.7)
How important is it to have fracture classification system agreement for all fractures, such as the use of AO/OTA? | 4 | 8.7 (2.0)
How important is it to have established, minimum set of reported patient factors (clinical, demographic) | 5 | 8.7 (1.7)
How important is it to have established, consistent recording of post-acute care, rehabilitation (site, amount, timing) | 6 (tie) | 8.2 (2.4)
How important is it to have fracture classification system agreement for stable/unstable intertrochanteric fractures? | 6 (tie) | 8.0 (2.1)
How important is it to have established, consistent use of intermediate outcomes (complications, revisions) | 8 | 8.2 (1.9)
How important is it to have established, clinically meaningful measures sensitive to differences in implant classes | 9 | 7.6 (1.9)
How important is it to have established, consistent definitions of surgical quality (e.g., technical quality such as quality of reduction, implant position, cup placement | 10 | 6.4 (3.2)
How important is it to have established, consistent recording of family and social support items | 11 | 6.9 (2.9)
How important is it to include the use of anabolic agents | 12 | 6.0 (2.4)
How important is it to have an established, consistent set of surgeon factors (e.g., surgeon experience, board certification, fellowship training, case volume) | 13 | 5.7 (2.4)

For rank: 1=high. Importance was rated using a scale of 1(not important) to 10 (very important)

The following items were also rated as highly important by stakeholders: the general concepts of using a comprehensive conceptual model upon which to base study design (importance = 8.5, SD 1.5); capturing baseline comorbidities as separate predictive factors to determine possible interactions with treatment responses (importance = 8.3, SD 2.2); capturing treatment trajectories over time (importance = 8.0, SD 1.8); addressing the representativeness of patient samples (importance = 8.0, SD 1.9); and addressing which research questions can be answered through the use of registry data (importance = 8.2, SD 1.9). However, stakeholders assigned lower priority scores to linking hip fracture research design initiatives with other coordinated research efforts, such as the National Institutes of Health Patient-Reported Outcomes Measurement Information System (PROMIS) patient outcome measurement initiative (importance = 3.9, SD 2.9).

Assuming that critical measurement issues had been resolved through a consensus conference, stakeholders then ranked hip fracture research question and theme area priorities. Table 3 provides the rankings for these research questions. Of the top seven ranked research questions, only three, treatments for frail elderly patients and the treatment of displaced femoral neck fractures and unstable intertrochanteric hip fractures, were rated by a strong majority as answerable by RCTs. The top three priority research questions, which were related to functional recovery trajectories and the impact of suboptimal surgical quality on function, were rated as not good candidates for RCT research.

Table 3 Stakeholder ranking of research questions

Item | | Rank (1=high) | # Yes (Question is good RCT candidate)
1. | Functional recovery trajectories
_ | What predicts short time-to-recovery after hip fracture? | 1 | 3
_ | What predicts functional outcomes after 1 year, especially 1–2 years after hip fracture? | 2 | 3
_ | What is the impact of suboptimal surgical quality on functional outcomes? | 3 | 0
2. | Patient populations:
_ | What treatment approach works best for patients admitted from nursing homes vs. community? | 4 | 5
_ | Do certain procedures (e.g., internal fixation) work better than others for frail older patients? | 5 | 7
_ | Are most fragile patients more or less likely to have suboptimal fracture reduction/implant position than the most active, mobile patients (making them higher risk for implant failure?) | 6 (tie) | 1
_ | Which procedures are better for patients with dementia? | 10 | 3
3. | Condition specific questions
_ | What is the optimal treatment for displaced femoral neck fractures? | 6 (tie) | 8
_ | What is the optimal treatment for “unstable” intertrochanteric hip fractures? | 8 | 8
_ | What is the optimal treatment for subtrochanteric hip fractures? | 9 | 6
4. | Implant specific comparisons/head-to-head trials
_ | Between class comparisons (e.g., IM nail vs screws) | 11 | 6
_ | Within-class comparison of arthroplasty – cement vs not | 12 | 5
_ | Within-class comparison of number and placement of screws | 13 | 4
_ | Within-class comparison of plate length, position | 14 | 4
_ | Within-class comparison of nail length (IMN) | 15 | 5

Responses to the question “what are the top three research areas for which registry data would be most useful” mirrored the results of the RCT ratings. The most frequently cited research areas included patient characteristics, fracture type and implant use, and outcomes, essentially to determine prognostic factors for functional recovery.

## Dissemination of Research Recommendations

Stakeholders provided feedback via email on potential ways to incentivize researchers to follow the research recommendations. Since it is essential that individual study results are comparable with other studies to maximize the research benefit of each RCT, consensus conference recommendations on topics such as general and condition-specific outcomes assessments to include with each study must be disseminated with sufficient clarity and impact to surgeons and researchers to ultimately improve research practices. Ultimately, incentives will be needed to encourage researchers to adopt the principles espoused here. As such, the following consensus building mechanisms were endorsed by the stakeholders:

- Create a set of study design and outcome measurement recommendations, similar to CONSORT, for journals to adopt as a mandatory publication requirement for hip fracture research. Simultaneous manuscript publications in top orthopaedic journals, such as the Journal of Bone & Joint Surgery, Clinical Orthopaedics and Related Research, Journal of International Orthopaedics, and the Journal of Orthopaedic Trauma, as well as placing the recommendations online for reference. This is the same approach that was used to disseminate CONSORT recommendations.2
- Podium presentations and symposia proposals for annual professional meetings of the Orthopaedic Trauma Association and the American Academy of Orthopaedic Surgeons calling for adoption of the recommendations.
- Encourage research funders to use a similar set of recommendations in writing requests for proposals, or scoring submitted research proposals.