# References

1 Butler M, Forte M, Kane R, et al. Treatment of common hip fractures. Evidence Report/Technology Assessment No. 184. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. HHSA 290 2007 10064 1). Rockville, MD. August. 2009.
2 Moher D, Schulz K, Altman D. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. Annals of Internal Medicine. Apr. 17. 2001;134(8):657-662. [pmid: 11304106].
3 Department of Commerce. Office of the Chief Information Officer WebPage. The Paperwork Reduction Act and Informations Collections Policy. Available at http://www.whitehouse.gov/sites/default/files/omb/inforeg/statpolicy/standards_stat_surveys.pdf. Accessed August 31, 2010.