# Methods

This section provides a brief overview of the methods employed for this project. Please refer to Appendixes A through C for more detailed project methods.

## Identifying Ongoing Studies

We performed a search to locate relevant, recently completed and currently ongoing hip fracture studies that potentially addressed existing knowledge gaps. Additionally, searches were carried out in Medline for recent publications that became available subsequent to the 2009 systematic review. ClinicalTrials.gov (http://clinicaltrials.gov), the WHO International Clinical Trials Registry Platform (ICTRP) (http://www.who.int/ictrp/en/), and the National Institutes of Health Research Portfolio Online Reporting Tool (RePORT) (http://projectreporter.nih.gov/reporter.cfm) web-based trial registries were searched for relevant ongoing studies. Studies were matched to the previously identified hip fracture research gaps and provided to stakeholders for comment.

## Engaging Stakeholders, Researchers, and Funders

We formed a 21-member stakeholder group with broad representation from orthopaedic surgeon-researchers, epidemiologists, professional organizations, federal and foundation research funders, healthcare payors, and device industry representatives. We sought stakeholders who were familiar with current hip fracture research practices and knowledge of research design since the identified research gaps were methodological in nature.

A conference call with 14 available stakeholders was held in June 2010, to discuss the state of hip fracture research, solicit feedback on the consolidated list of research gap areas, and to refine the research questions. Participating stakeholders were representative of the larger stakeholder group; no type of stakeholder was unrepresented on the call. All 21 stakeholders were provided the Executive Summary from the original systematic review to help set the context for the conference call. Identified ongoing studies were combined with the list of identified research gaps from the original 2009 systematic review to generate a table of specific hip fracture knowledge gaps. This table was also provided prior to the stakeholders prior to the conference call.

Email was used for all other stakeholder contact. All 21 stakeholders received a summary of the conference call, and a revised research agenda based on stakeholder input, and were asked to provide further comment or clarification if warranted. We conducted a prioritization activity by email to a subgroup of 10 stakeholders. We used stakeholder comments and the Revised Research Agenda to develop a two-part prioritization activity asking stakeholders to rate the importance of various research concepts, and rank a list of hip fracture outcomes measurement issues. A representative sub-group of seven non-government stakeholders, representing payors, device manufacturers, and a diverse set of researchers, and three government employees, participated in this activity. Additional feedback was sought from all stakeholders on potential ways to disseminate recommendations to improve research quality among orthopaedic surgeons and epidemiologists/observational researchers, and how to best incentivize all researchers to improve study quality.

## Handling Conflicts of Interest

Disclosure forms of conflicts of interests were collected from all stakeholders. While no one was prohibited from participating based on their disclosures, the forms would have allowed us to temper any stakeholder’s contributions if the conversation topic warranted attention.

Multiple representatives of different device industry manufacturers participated. This was done in order to avoid the perception of undue influence by any one manufacturing firm.

Although the intention was to keep a fire-wall between funders and researchers, scheduling did not allow this option. However, this fact did not appear to inhibit participation. Since the conference call discussion remained at the general level of how the field needs to address the existing research gaps, rather than the development of specific research questions, any issues of unfair advantage for future research proposals appears very low. Stakeholder responses to ranking specific research questions on the prioritization activity were handled by email, thus researchers and funders were blind to the other’s stated opinions.

## Determining Appropriate and Feasible Study Designs

Information regarding appropriate and feasible study designs was gathered during the stakeholder conference call and through the prioritization activity. The majority of the conference call was spent discussing the gap between ideal and current research design practices, and problematic measurement issues that limit the comparability of study results. Suggestions regarding the range of possible study designs (i.e., RCT, observational studies, and the use of registries), and opinions about issues in outcomes assessment were obtained. The prioritization activity asked whether or not each identified research question could be adequately addressed with an RCT. The activity also asked stakeholders to suggest topics for which research based on registries would be most useful.

## Prioritizing Research

We used stakeholder comments and a revised research agenda to develop a two-part email prioritization activity for a sub-group of stakeholders to complete. The stakeholders were asked to rate on a scale of 1 (least important) to 10 (most important) the relative importance of methods issues that could be resolved in a consensus conference. They were also asked to rank current hip fracture outcomes measurement issues that require resolution to advance the field, starting with 1 as the highest priority (most limiting) issue. Stakeholders were then asked to rank specific research questions, again starting with 1 as the highest priority question. Prioritization activity results were tabulated and ranked based on mean scores.