# Stakeholders

Lauren Beaupre, P.T., Ph.D.

University of Alberta

Edmonton, AB, CANADA

Shamiram R, Feinglass, M.D., M.P.H.

Global Medical Affairs

Zimmer, Inc.

Warsaw, IN

Evan Hadley, M.D.

Division of Geriatrics and Clinical Gerontology

National Institute on Aging

Bethesda, MD

Jane M. Jacob, Ph.D., C.C.R.P.

Clinical Affairs

DJO Surgical

Austin, TX

Kenneth J. Koval, M.D.

Dartmouth Hitchcock Medical Center

Wilmot, NH

Jay Magaziner, Ph.D., M.S.Hyg.

Department of Epidemiology and Public Health

University of Maryland School of Medicine

Baltimore, MD

Charles M. Turkelson, Ph.D.

Research and Scientific Affairs Department

Academy of Orthopaedic Surgeons

Rosemont, IL

Thomas Becker, M.D., M.B.A.

Care Management and Reimbursement

Medica Health Plans

Minnetonka, MN

Keith E. Folkert, M.D., M.H.A.

Health Management and Medical Policy

Blue Cross and Blue Shield of Minnesota

Eagan, MN

Edward Harvey, M.D.C.M., M.Sc., F.R.C.S.C.

Orthopaedic Trauma

Montreal General Hospital

Montreal, QC, CANADA

Lyndon Joseph, Ph.D.

Division of Geriatrics and Clinical Gerontology

National Institute on Aging, NIH, DHHS

Bethesda, MD

Joseph Lane, M.D.

Metabolic Bone Disease Service

Hospital for Special Surgery

New York, NY

Elliot J. Roth, M.D.

Department of Physical Medicine and Rehabilitation

Northwestern University Feinberg School of Medicine

Rehabilitation Institute of Chicago

Chicago, IL

We would also like to thank eight stakeholders who preferred to remain anonymous.