# Executive Summary

The Effective Health Care Program was initiated in 2005 to provide valid evidence about the comparative effectiveness of different medical interventions. The object is to help consumers, health care providers, and others in making informed choices among treatment alternatives. Through its comparative effectiveness reviews, the program supports systematic appraisals of existing scientific evidence regarding treatments for high-priority health conditions. It also promotes and generates new scientific evidence by identifying gaps in existing scientific evidence and supporting new research. The program puts special emphasis on translating findings into a variety of useful formats for different stakeholders, including consumers.

The full report and this summary are available at www.effectivehealthcare.ahrq.gov/reports/final.cfm.

## Background

The 2009 systematic literature review “Treatments of Common Hip Fractures” was conducted for the American Academy of Orthopaedic Surgeons to provide input for their development of clinical guidelines for surgical procedures for implantable devices. The nominator was interested in understanding the interaction between patient factors, types of hip fractures, types of surgical implantable devices, and outcomes. The subsequent systematic review conducted by the Minnesota Evidence-based Practice Center (EPC) was unable to fully address the research questions with the existing literature because of (a) the limited perspective of discipline-specific investigations (i.e. orthopaedic or epidemiology), which tended to use incomplete sets of important independent variables in study designs and models, and (b) the generally low quality of hip fracture outcome studies to date, where specific populations were poorly defined, and the use of inconsistent outcome variables and assessment tools prevented aggregating or even comparing results. The objective of this project was to work with stakeholder groups with an interest in improving hip fracture patient outcomes to examine, refine, and prioritize research questions and methodological approaches that would fill the existing research knowledge gaps in hip fracture treatment.

## Methods

We formed a 21-member stakeholder group with representation from orthopaedic surgeon-researchers, epidemiologists, professional organizations, Federal and foundation research funders, healthcare payors, and device industry representatives. We simultaneously performed a search to locate relevant, recently-completed and currently ongoing hip fracture outcomes studies that potentially addressed existing knowledge gaps. Search results were combined with the list of identified research gaps from the original 2009 systematic review to generate a list of specific hip fracture knowledge gaps for email distribution to the stakeholders. A conference call with 14 stakeholders was held to discuss the state of hip fracture research, solicit feedback on the consolidated list of research gap areas, and to refine the research questions. A summary of the conference call and one-page Revised Hip Fracture Research Agenda was sent out to stakeholders for comment by email. The revised agenda included two theme areas: measurement and study design.

We used stakeholder comments and the Revised Research Agenda to develop a two-part prioritization activity. A subgroup of 10 stakeholders, representing payors, device manufacturers, and a diverse set of researchers, rated the importance of various research concepts, and ranked a list of hip fracture outcomes measurement issues. These questions were placed within the context of developing an agenda for a consensus conference as means to resolve fundamental measurement issues. They also ranked specific research questions and whether or not each could be addressed with a randomized controlled trial (RCT). Stakeholders were asked to suggest research topics for which registry-based investigations would be most useful. Prioritization activity results were tabulated and ranked based on mean scores. Finally, additional feedback was sought from all stakeholders on potential ways to disseminate recommendations to improve research quality among orthopaedic surgeons and epidemiologists/observational researchers, and how to best incentivize both orthopaedic and epidemiology researchers to improve study quality.

## Results

No research gap, either a methods issue or a research question, was fully addressed by identified ongoing studies or recently published trials.

Executive Summary Table 1 provides a summary of stakeholder rankings for consensus conference topics. All items related to measurement were rated as moderately (scores in the 6 to 7 range) to highly important (scores in the 8 to 9 range). High priority and high importance was placed on a broad set of measurement consistency issues that are more generally accepted as important to researchers across disciplines, such as priority outcomes to be reported across studies, and establishing definitions and the recommended use of pertinent predictor variables. Items that received lower priority scores are largely items which are associated with one specific discipline or another, be it a surgical view, a rehabilitation view, or an epidemiological view. The trending toward wider standard deviations among lower-ranked conference topics also highlights the wider variation in the stakeholder responses to these items.

Executive Summary Table 1 Stakeholder ranking of consensus conference topics

Consensus Conference Item | Rank
How important is it to have established, consistent reporting of post-treatment outcomes (function, pain, living situation, mortality, quality of life)? | 1
How important is it to have established, consistent definitions of the types of fracture? | 2
How important is it to have a tool box of validated outcomes measures? | 3
How important is it to have fracture classification system agreement for all fractures, such as the use of AO/OTA? | 4
How important is it to have established, minimum set of reported patient factors (clinical, demographic)? | 5
How important is it to have established, consistent recording of post-acute care, rehabilitation (site, amount, timing)? | 6 (tie)
How important is it to have fracture classification system agreement for stable/unstable intertrochanteric fractures? | 6 (tie)
How important is it to have established, consistent use of intermediate outcomes (complications, revisions)? | 8
How important is it to have established, clinically meaningful measures sensitive to differences in implant classes? | 9
How important is it to have established, consistent definitions of surgical quality (e.g., technical quality such as quality of reduction, implant position, cup placement? | 10
How important is it to have established, consistent recording of family and social support items? | 11
How important is it to include the use of anabolic agents? | 12
How important is it to have an established, consistent set of surgeon factors (e.g., surgeon experience, board certification, fellowship training, case volume)? | 13

For rank: 1=high. Importance was rated using a scale of 1(not important) to 10 (very important)

The following items were also rated as highly important by stakeholders: the general concepts of using a comprehensive conceptual model upon which to base study design; capturing baseline comorbidities as separate predictive factors to determine possible interactions with treatment responses; capturing treatment trajectories over time; addressing the representativeness of patient samples; and addressing which research questions can be answered through the use of registry data. However, stakeholders assigned lower priority scores to linking hip fracture research design initiatives with other coordinated research efforts, such as the National Institutes of Health Patient-Reported Outcomes Measurement Information System (PROMIS) patient outcome measurement initiative.

Stakeholders then ranked hip fracture research question and theme area priorities. Executive Summary Table 2 provides the rankings for these research questions. Of the top seven ranked research questions, only three, treatments for frail elderly patients and the treatment of displaced femoral neck fractures and unstable intertrochanteric hip fractures, were rated by a strong majority as answerable by RCTs. The top three priority research questions, which were related to functional recovery trajectories and the impact of suboptimal surgical quality on function, were rated as not good candidates for RCT research.

Executive Summary Table 2 Stakeholder ranking of research questions

Item | | Rank
1. | Functional recovery trajectories
_ | What predicts short time-to-recovery after hip fracture? | 1
_ | What predicts functional outcomes after 1 year, especially 1–2 years after hip fracture? | 2
_ | What is the impact of suboptimal surgical quality on functional outcomes? | 3
2. | Patient populations:
_ | What treatment approach works best for patients admitted from nursing homes vs. community? | 4
_ | Do certain procedures (e.g., internal fixation) work better than others for frail older patients? | 5
_ | Are most fragile patients more or less likely to have suboptimal fracture reduction/implant position than the most active, mobile patients (making them higher risk for implant failure?) | 6 (tie)
_ | Which procedures are better for patients with dementia? | 10
3. | Condition specific questions
_ | What is the optimal treatment for displaced femoral neck fractures? | 6 (tie)
_ | What is the optimal treatment for “unstable” intertrochanteric hip fractures? | 8
_ | What is the optimal treatment for subtrochanteric hip fractures? | 9
4. | Implant specific comparisons/head-to-head trials
_ | Between class comparisons (e.g., IM nail vs screws) | 11
_ | Within-class comparison of arthroplasty – cement vs not | 12
_ | Within-class comparison of number and placement of screws | 13
_ | Within-class comparison of plate length, position | 14
_ | Within-class comparison of nail length (IMN) | 15

Responses to the question “What are the top three research areas for which registry data would be most useful?” mirrored the results of the RCT ratings. The most frequently cited research areas included patient characteristics, fracture type and implant use, and outcomes, essentially to determine prognostic factors for functional recovery.

Stakeholders also provided feedback via email on potential ways to incentivize researchers to follow the research recommendations. Since it is essential that individual study results are comparable with other studies to maximize the research benefit of each RCT, consensus conference recommendations on topics such as general and condition-specific outcomes assessments to include with each study must be disseminated with sufficient clarity and impact to surgeons and researchers to ultimately improve research practices. Ultimately, incentives will be needed to encourage researchers to adopt the principles espoused here. As such, the following consensus building mechanisms were endorsed by the stakeholders:

- Create a set of study design and outcome measurement recommendation, similar to CONsolidated Standards Of Reporting Trials (CONSORT), for journals to adopt as a mandatory publication requirement for hip fracture research. Simultaneously publish recommendations in top orthopaedic journals, such as the Journal of Bone & Joint Surgery, Clinical Orthopaedics and Related Research, the Journal of International Orthopaedics, and the Journal of Orthopaedic Trauma. This is the same approach that was used to disseminate CONSORT recommendations.2
- Podium presentations and symposia proposals for annual professional meetings of the Orthopaedic Trauma Association, and the American Academy of Orthopaedic Surgeons calling for adoption of the recommendations.
- Encourage research funders to use a similar set of recommendations in writing requests for proposals or scoring submitted research proposals.

## Conclusions

This pilot project engaged hip fracture experts, orthopaedic surgeon-researchers, professional organization and industry representatives, and funders, to indentify and prioritize critical hip fracture outcomes knowledge gaps, and the best approaches to resolving them. This project provided valuable information that can advance hip fracture outcomes to improve the quality of care for his high-risk patient population. Successively refined research gap documents evaluated by stakeholders, augmented with a conference call discussion, proved to be a workable way to obtain both information on gaps and the opinions of various entities regarding the prioritization of cutting-edge issues in the treatment of hip fracture patients.

Agreement on the need for improvement in research measurement and methods across all types of hip fracture investigators was high among this group of experts. Similarly, priority areas for investigation showed a high degree of agreement across stakeholders, suggesting areas of focus for future hip fracture research efforts.

Although our panel of stakeholders identified specific areas for research improvements, the comments were principally directed toward orthopaedic rather than non-orthopaedic researchers. Further refinements to research recommendations that are specific to orthopaedic surgeons or epidemiologists could readily be determined within a consensus conference setting. However, this pilot project could not determine whether the majority of orthopaedic surgeons who treat hip fracture patients or epidemiologists who evaluate hip fracture outcomes perceive a need for research or measurement improvements. Such a determination would be essential if improvements were to be implemented in the broader professional and research communities.

Although ideas were generated for incentivizing research improvements, little is known about ways to change surgeon-researcher behavior in the conduct of clinical studies. Incentives need to offset the challenges of conducting clinical outcomes studies. Higher standards or scores by funding bodies for optimally-designed and measured clinical studies was one mechanism that received stakeholder support. Ultimately, several approaches to target providers across multiple settings may encourage improved outcomes, although the optimal incentivizing mechanism remains unknown.