# Discussion

A select group of hip fracture outcomes experts, professional organization representatives, funders, payors and industry representatives showed a high level of agreement in the identification and significance ranking of current hip fracture outcomes issues that remain unresolved.

The use of a consensus conference as means to resolve fundamental measurement issues that continue to handicap hip fracture outcomes investigations received unanimous support, along with strong agreement on the issues that require resolution by that mechanism. The larger standard deviations for lower ranked consensus conference items demonstrate a wider variance in perceptions among stakeholders. This variability can be interpreted as honest disagreement or as evidence of a lack of consensus on important research design issues, although the scope of this project was not intended to make that specification. Instead, we use the results as yet more evidence that a consensus conference, where ideas can be shared and debated, remains an essential task to be completed in order to advance the field.

The top three research questions ranked by stakeholders relate to the timing of functional recovery and the relationship between surgical quality and functional outcomes. These questions map to Gaps B-F identified in Figure 1, as understanding patient, setting, and treatment factors are necessary components to developing knowledge regarding predictors of functional recovery, which in turn require valid and reliable outcome measurements. Information on functional recovery trajectories, both early and late after hip fracture surgery, represent refinements of clinical investigations to date. Resolution of timing issues will enable better comparisons to be made of the value of one device class over another if the benefits are short-lived. Stakeholder rankings, combined with current orthopaedic clinical trials that include surgical quality assessments, suggest acknowledgement by surgeons that unlike pharmaceutical trials, variation in treatment quality may impact outcomes (Gap C). The association between surgical quality and outcomes appeared only minimally in the orthopaedic hip fracture literature 15–20 years ago, then essentially disappeared until recently.1

Two of three areas that ranked highest among stakeholders for RCT investigation reflect current high-visibility controversies in orthopaedics, including the optimal treatment for patients with displaced femoral neck fractures or unstable intertrochanteric hip fractures. Using the conceptual model in Figure 1 as guidance would lead to well-designed RCTs. The third area, the optimal treatments for frail elderly hip fracture patients, reflects the changing demographics of U.S. hip fracture patients, and the historically low involvement of the very old in hip fracture clinical trials to date, leaving a broad knowledge gap in the treatment of this growing and high-risk segment of the population (Gap A).

Although the experts who participated in this project were selected as representative of broader professional and research groups with hip outcomes interests, the prioritization activity was limited to a small subsample of the stakeholder group, and the results may not reflect the priorities of the general stakeholder population. The sample size was limited by the Paperwork Reduction Act and Information Collections Policy (44 USC 3501–3520), administered by the Office of Management and Budget.3 The Act was designed to minimize the paperwork burden on the public, assure high quality data are obtained, and minimize costs. However, the approval process to allow greater than nine non-government participants exceeded the length of time available to complete the project. Instead, we sought to minimize the burden by using a small sample size and informal discussions via teleconference.

Fundamental concepts implicit in this project, including the assumption that orthopaedic surgeons collectively recognize that their clinical research would benefit from design and measurement improvements, and that the optimal outcomes to measure are patient, rather than complications-based, were not explicitly determined in this pilot project. Such potentially-delicate intraprofessional concepts may be better assessed from within by surgeon opinion leaders and professional organizations.

We found strong agreement on mechanisms for the dissemination of consensus conference recommendations for improved research designs, study quality and outcomes measurement among stakeholders. However, the more challenging issues of incentivizing surgeons and epidemiologists to improve study quality received less-definitive recommendations. Orthopaedic and orthopaedic research opinion leaders can lead by example in future clinical outcomes studies, since suggestions to improve research practices may be best heard when delivered by opinion leaders within the professions, rather than by outside entities. Varied approaches may be the most successful. Closely following that, funding agencies, including Foundations, would benefit the processes greatly by adopting a set of standards for the conduct of RCTs with the goal of comparability across studies to maximize outcome information.