# Conclusions

This pilot project engaged hip fracture experts, orthopaedic surgeon-researchers, professional organization and industry representatives, and funders, to indentify and prioritize critical hip fracture outcomes knowledge gaps, and the best approaches to resolving them. This project provided valuable information that can advance hip fracture outcomes to improve the quality of care for his high-risk patient population. Successively refined research gap documents evaluated by stakeholders, augmented with a conference call discussion, proved to be a workable way to obtain both information on gaps, and the opinions of various entities regarding the prioritization of cutting-edge issues in the treatment of hip fracture patients.

Agreement on the need for improvement in research measurement and methods across all types of hip fracture investigators was high among this group of experts. Similarly, priority areas for investigation showed a high-degree of agreement across stakeholders, suggesting areas of focus for future hip fracture research efforts.

Although our panel of stakeholders identified specific areas for research improvements, the comments were principally directed toward orthopaedic rather than non-orthopaedic researchers. Further refinements to research recommendations that are specific to orthopaedic surgeons or epidemiologists could readily be determined within a consensus conference setting. However, this pilot project could not determine whether the majority of orthopaedic surgeons who treat hip fracture patients, or epidemiologists who evaluate hip fracture outcomes, perceive a need for research or measurement improvements. Such a determination would be essential if improvements were to be implemented in the broader professional and research communities.

Although ideas were generated for incentivizing research improvements, little is known about ways to change surgeon-researcher behavior in the conduct of clinical studies. Incentives need to offset challenges of conducting clinical outcomes studies. Higher standards or scores by funding bodies for optimally-designed and measured clinical studies was one mechanism that received stakeholder support. Ultimately, several approaches to target providers across multiple settings may encourage improved outcomes, although the optimal incentivizing mechanism remains unknown.