# Background

The systematic review “Treatments of Common Hip Fractures,” completed in August 2009, was the result of a topic nomination made by the American Academy of Orthopaedic Surgeons, who were planning to formulate clinical guidelines for surgical procedures for implantable devices. The nominator was interested in understanding the interaction between patient factors, fracture types, types of surgical implants, and outcomes.

Following refinement, the key questions addressed were:

- Key Question 1. What is the relationship between patient variables (e.g., demographic factors, comorbidities), the type of fracture (i.e., intertrochanteric, subtrochanteric, subcapital) and post-treatment outcomes (e.g., pain, mobility, mortality)?
- Key Question 2. What is the relationship between the type of fracture (i.e., intertrochanteric, subtrochanteric, subcapital) and post-treatment outcomes (e.g., pain, mobility, mortality)?
- Key Question 3. What is the relationship between implant variables (e.g., position, material, method, and design of implant) and patient post-treatment outcomes (e.g., pain, mobility, mortality)?
- Key Question 4. What is the relationship between the type of intervention (e.g., internal fixation versus arthroplasty) and patient post-treatment outcomes (e.g., pain, mobility, mortality)?

The systematic review was unable to fully answer the research questions with the existing literature generally because of two main factors: (1) the limited perspective of discipline-specific investigations (i.e., orthopaedics or epidemiology), which tended to use incomplete sets of important independent variables in study designs and models, and (2) the generally low quality of hip fracture outcome studies to date, where specific populations were poorly defined, and the use of inconsistent outcome variables prevented aggregating or even comparing results. The latter problem of inconsistent outcomes measures is a general issue for most mobility literature.

Additionally, very little literature was available to provide evidence for the multitude of comparisons of device variables within a class of devices, i.e. number of screws or the specific design for sliding hip screw implants. With this inability to show either greater effectiveness or equivalency between device variables, or between devices within a class, aggregating the comparisons at the level of head to head comparisons of classes of devices becomes problematic.

## Research Gaps

A number of recommendations were made to improve future research to support developing useful guidelines for orthopaedic surgeons. Table 1, a reproduction of a table from the original report, summarizes the research recommendations, which were largely aimed at improving study design and conduct consistent with CONSORT quality recommendations.

Table 1 Treatment of common hip fractures report: future research recommendations1

Key Question | Results of Literature Review | Types of Studies Needed to Answer Question | Future Research Recommendation
1. What is the relationship between patient variables, the type of fracture and post-treatment outcomes? | Age, gender, prefracture functioning, and cognitive impairment appear to be related to mortality and functional outcomes. | Comprehensive studies that include variables that describe salient patient characteristics, fracture type, and surgical factors | - Include nursing home or dementia patients and distinguish them in analysis.; - Include comprehensive set of predictor variables.; - Collaboration between epidemiology and surgeon investigators.; - Include stable/unstable intertrochanteric subtypes (AO/OTA classification) in analyses, as well as surgical treatments; does outcome depend more on reduction than implant?
2. What is the relationship between the type of fracture and post-treatment outcomes? | Fracture type is not independently related to patient outcomes in observational literature, but the literature has not generally examined stable and unstable intertrochanteric fractures. | Comprehensive studies that include variables that describe salient patient characteristics, fracture type, and surgical factors
3. What is the relationship between implant variables and patient post-treatment outcomes? | Few studies show dramatic effects on patient level outcomes. | Well-designed RCTs. Likely multicenter studies will be necessary to attain adequately powered sample sizes. | - Consistent use of validated outcome measures.; - Quantify and report quality of surgical technique.; - Reliable reporting of stable/unstable intertrochanteric fracture subtypes.; - More inclusive conceptual models.; - Data pooling.; - Collaborate with observational investigators.
4. What is the relationship between the type of intervention and patient post-treatment outcomes? | Few studies show dramatic effects on patient level outcomes. | Well-designed RCTs. Likely multicenter studies will be necessary to attain adequately powered sample sizes.

Figure 1 provides an illustration of the general conceptual model for important components in the surgical treatment of common hip fractures and their relationships to patient outcomes and the identified research gaps provided in Table 1 above. The highlighted factors are those which were explicitly addressed in the key questions, that is, patient demographic and clinical factors, including fracture type, type of treatment, and patient outcomes such as function, pain, and quality of life. The major research gaps identified in the original report can be categorized into the two main areas discussed earlier, e.g., discipline-specific study issues and studies of low quality, and located within this conceptual model.

Figure 1 Conceptual model

Figure 1 provides an illustration of the general conceptual model for important components in the surgical treatment of common hip fractures and their relationships to patient outcomes and the identified research gaps provided in Table 1. The highlighted factors are those which were explicitly addressed in the key questions, that is, patient demographic and clinical factors, including fracture type, type of treatment, and patient outcomes such as function, pain, and quality of life. The major research gaps identified in the original report can be categorized into the two main areas discussed earlier, e.g., discipline-specific study issues and studies of low quality, and located within this conceptual model.

Discipline-specific studies. There is one major gap in this category: Gap A. Gap A in Figure 1 refers to the lack of a comprehensive research view in the majority of hip fracture outcomes studies. Specifically, studies to date lack a broad set of predictor variables that sufficiently account for non-treatment factors, such as baseline patient status, clinical features, patient characteristics, and setting/contextual factors, that may affect patient outcomes. Surgeon investigators tend to exclude setting and patient factors, while observational researchers tend to omit condition and treatment-specific details. This problem is exacerbated by the lack of research collaboration between epidemiologic and orthopaedic surgeon investigators.

Low quality outcome studies. There are four major gaps in this category. Gap B, located with the patient outcomes in Figure 1, relates to the inconsistent use of validated outcome measures. Gap C relates to the incomplete reporting of treatment settings factors, such as hospital volume and surgical variables, such as surgical technique or surgeon experience with each treatment/device. Gap D relates to the treatment-specific details, an omission in many observational studies. This is further complicated by a lack of head to head trials comparing various components of device characteristics to establish whether equivalency or improved effectiveness of specific components of devices can be demonstrated. Gap E relates to the inadequate classification of clinical patient factors, i.e. stable or unstable fractures and the type of fracture. Gap F addresses patient populations that are not well represented in the current literature, such as patients with cognitive impairments and dementia, or patients admitted from nursing homes and other institutional residences.

The focus of the original systematic review was on patient-related outcomes, such as function, pain, and quality of life, in the recovery after hip fracture. In order to fully address these outcomes, the quality of research evidence for these outcomes will need to improve. Therefore, the goals of this hip fracture research needs project were:

1. To list, update, and prioritize research gap areas that need to be filled to advance hip fracture outcomes knowledge.
2. To identify specific treatment and outcome measurement issues which require resolution to advance the field in meaningful ways.
3. To suggest the best research method(s) to address specific knowledge gaps (RCT or other research design, consensus conference of experts, other), and
4. Where a consensus conference(s) is/are indicated, suggest ways to disseminate conference recommendations to the field (orthopaedics, epidemiology) so recommendations can be implemented in research.