# Appendixes

Appendix A Search Strategy for Recently Published and Ongoing Studies

Appendix B List of Ongoing and Recently Published Studies

Appendix C Prioritization Methods and Tools