# Prioritization Methods and Tools

## Specific Methods

1. We formed stakeholder groups with representation from orthopaedic surgeon-researchers, epidemiologists, professional organizations, federal and foundation research funders, payors and device industry representatives.

We sought stakeholders who were familiar with current hip fracture research practices and knowledge of research design since the identified research gaps were methodological in nature. We first constructed a general list of the types of care providers, researchers, professionals and funders that represent various stakeholder groups and perspectives who hold an interest in hip fracture outcomes. The specific list of stakeholders was then constructed. The Technical Expert Panel (TEP) members from the 2009 project were included (orthopedic and epidemiologic researchers, plus a representative from the topic requestor, the American Academy of Orthopedic Surgeons (AAOS)). Additional researchers with broad hip fracture outcomes and rehabilitation interests were added, including physical therapy, an international orthopaedic researcher and epidemiologic researchers. We included representatives from the major orthopaedic and aging outcomes funding agencies (government, orthopaedic associations and foundations). In addition to the AAOS, several professional organizations were included: the Orthopaedic Trauma Association (OTA) and the American Academy of Physical Medicine and Rehabilitation (AAPM&R). Finally, we listed large payors of hip fracture services, a Medicare advisory group, and industry representatives (device manufacturers). Where additional contacts were needed, prior TEP members were consulted for individual suggestions to generate a comprehensive stakeholder lost to encompass broad hip fracture treatment perspectives. This process resulted in a 21 member stakeholder group including orthopaedic surgeon-researchers, epidemiologists, professional organizations, federal and foundation research funders, healthcare payors, and device industry representatives.

The list of research gaps identified in the August 2009 report served as the starting point for this project based on the four key questions that were the focus of the 2009 report. A more detailed table of research gaps was then constructed by the MN EPC faculty from the Discussion within the 2009 report, and used as the basis for a stakeholder conference call. Table C-1 provides a summary table of the research gaps that was provided to the stakeholders. Column 1 lists the key questions (1–4) from the 2009 hip fracture report, plus additional knowledge gap areas that are not specifically identified within the key questions. Column 2 lists the hip fracture research gap areas that were identified in the report, with additional specificity regarding research gaps. Column 3 has specific population needs that the MN EPC has identified.

Table C-1 Research gaps table prepared for stakeholder conference call discussion

Key Question/Cross-cutting Issues | Research knowledge gaps | Under-studied populations | Ongoing studies that may address knowledge gaps
Interdisciplinary research | Lack of inclusive conceptual models which incorporate comprehensive set of predictor variables that sufficiently account for non-treatment factors that may influence outcomes | All patients
Outcomes measurement | Consistent use of validated quality of life and outcome assessment tools; - crosswalk studies for each measure; - consensus conference for minimum outcome measurement set | All patients
Fracture classifications | Consensus for:; - stable/unstable intertrochanteric fractures; - crosswalk of fracture classifications for comparability across studies | All patients
1. What is the relationship between patient variables, the type of fracture and patient post-treatment outcomes, such as pain and functioning? how patient factors, including fracture type, relate to patient outcomes | A. Relationship between baseline patient covariates and post-treatment outcomes; B. Relationship between type of fracture, and post-treatment outcomes, given the patient covariates (see Q2, A); a. how outcomes are modified by: inferior surgical quality, and/or using surgeon characteristics as proxy surgical quality; b. subgroup differences in fracture types?; C. How functional recovery trajectories differ by patient factors and fracture type, controlling for treatment; What predicts short time-to-recovery after hip fracture?; D. Functional trajectories after 1 year, especially 1–2 years after hip fracture; Factors associated with functional declines beyond 1 year after hip fracture | Outcomes and treatment differences:; a. patients admitted from nursing homes vs. community; b. cognitively-impaired patients from any setting; c. by race/ethnicity (changing U.S. demographics); d. by physiologic vs. chronologic age (active elderly); e. obese elderly; f. nutritionally-depleted vs. sarcopenic vs. frail elderly; - Isolated low energy hip fractures in older individuals (homogeneous clinical trial populations); - In which patients is the risk/benefit ratio too great for surgical treatment of a hip fracture? | NCT01051830 Care model for hip fracture patient with diabetes (Taiwan)
2. What is the relationship between the type of fracture and patient post-treatment outcomes? controlling for patient factors | A. Relationship between type of fracture, and post-treatment outcomes, controlling for patient covariates; B. What is the optimal treatment for displaced femoral neck fractures?; C. What is the optimal treatment for ‘unstable’ intertrochanteric hip fractures?; D. Which AO/OTA 31-A fracture patterns should be treated as unstable fractures?; E. Subtrochanteric fractures | All patients Subgroups: see 1B(b); a. patients admitted from nursing homes vs. community; b. cognitively-impaired patients from any setting; c. by race/ethnicity (changing U.S. demographics) | NCT00556842. HEALTH: hemiarthroplasty vs. THA NCT00557167. FAITH: internal fixation: pins vs. plate/screws
3. What is the relationship between implant variables and patient post-treatment outcomes? implant-specific | Incomplete sets of head-to-head trials.; A. What is the optimal treatment for displaced femoral neck fractures?; B. What is the optimal treatment for ‘unstable’ intertrochanteric hip fractures?; C. Within-class device comparisons:; - number and placement of screws; - plate length, position; - nail length (IMN); - arthroplasty-cement versus not; D. how outcomes are modified by:; - inferior surgical quality, regardless of device.; - Are some devices less forgiving of suboptimal surgical technique? | All patients, including specific high-risk subgroups | C: NCT00323232. SHS with 2 vs. 4 holes for 2 to 4 part IT fracture NCT00491673 (completed) cement vs. uncemented hemi for displaced FN fracture NCT00859378 cement vs. uncemented for FN NCT00800124. Cement vs. uncemented hemi for dislocated FN NCT00306917 (Trauma or elective?) NCT00736684 PFNA vs. Gamma3 nail for unstable IT NCT00546429? ATN Nail outcome study NCT00595634? INTUIT. InterTAN for unstable IT outcome study
4. What is the relationship between the type of intervention and patient post-treatment outcomes? device class comparisons; - how outcomes are modified by:; * inferior surgical quality, and/or; * using surgeon characteristics as a proxy for surgical quality | Incomplete sets of head-to-head trials.; A. Timing of functional recovery by device: does one class of device afford earlier return to function?; B. What is the optimal treatment for displaced femoral neck fractures?; C. What is the optimal treatment for ‘unstable’ intertrochanteric hip fractures?; D. How to best treat 75–85 year old femoral neck fracture patients; E. how outcomes are modified by:; - inferior surgical quality, regardless of device. Are some devices less forgiving of suboptimal surgical technique? | All patients, including specific high-risk subgroups:; a. is optimal technique more important to outcomes in some patient groups?; b. Are most fragile patients more or less likely to have suboptimal fracture reduction/implant position than the most active, mobile patients? | NCT00556842. HEALTH: hemiarthroplasty vs. THA NCT00557167. FAITH: internal fixation: pins vs. plate/screws NCT00621088 possible. Subtroch SHS vs. Intertran Nail NCT00597779 TFN vs. SHS for unstable IT NCT00664950. InterTAN Nail vs. SHS for IT NCT00829725 Parallel screws vs. TARGON implant for FN. NCT00555945. Gamma3 Nail vs. SHS for IT (REGAIN) NCT00317837. Bi vs. Uni-hemi for displaced FN NCT00764153. Hemi vs. Internal fix for displaced FN (also NCT00464230)

2. We simultaneously performed a search to locate relevant, recently-completed and currently on-going hip fracture outcomes studies that potentially addressed existing knowledge gaps. (See Appendix A for more search details.)

Search results were combined with the list of identified research gaps from the original systematic review to generate a list of specific hip fracture knowledge gaps for email distribution to the stakeholders prior to the stakeholder conference call. Column 4 in Table C-1 lists ongoing studies that may address some of the identified gaps, and was generated from ClinicalTrails.gov.

3. A conference call with stakeholders was held to solicit feedback on the consolidated list of research gap areas and to refine the research questions.

Preparatory materials including the Executive Summary from the original systematic review, Table C-1, directions for reading the table, and the Minnesota EPC follow-up plan for the subsequent ranking exercise were distributed to all 21 stakeholders prior to the conference call. Fourteen stakeholders, representing all major types of stakeholders, were available and participated in the conference call. Following the 1 hour conference call, convened by the Minnesota EPC, stakeholder feedback was used to refine a one-page Revised Hip Fracture Research Agenda. The revised research agenda was sent out to all 21 stakeholders for comment along with a summary of the call; it included two theme areas: measurement and design issues. This agenda is provided Table C-2.

Table C-2 Revised hip fracture research agenda

Measurement Issues | 1. Need to operationalize each element; - Intervention/procedure (including technical quality such as quality of reduction, implant position, cup placement); - Type of fracture; - Patient factors (clinical, demographic); - Surgeon factors (measures of surgeon quality, e.g. quality of initial reduction, placement of implants, appropriate sizing of femoral head endoprostheses); - Outcomes; - Post-treatment: function, pain, living situation, mortality quality of life; - Intermediate: complications, revisions; - Sensitivity to differences in implant classes but still meaningful; - Use of anabolic agents; - Role of post-acute care, rehabilitation (site, amount, timing); - Role of family support/Social support; 2. Toolbox of approved, validated measures; 3. Classification system for fractures (AO/OTA); - stable/unstable intertrochanteric fractures; 4. Within-class device comparisons:; - number and placement of screws; - plate length, position; - nail length (IMN); - arthroplasty-cement versus not; 5. Linkage with other ongoing efforts (e.g., PROMIS)
Design Issues | 6 Lack of inclusive conceptual models that incorporate comprehensive set of predictor variables (reflecting clinical and epidemiological perspectives) in study analyses that sufficiently account for factors that may influence outcomes (see attached model); 7 Capture baseline comorbidities as separate predictive factors and for interactions with treatment; 8 Examine clinical trajectories. How long should benefits persist?; - Frequency and timing of follow-ups; 9 Head-to-head trials; - Within-class comparisons (e.g., features of sliding hip screws); - Between class comparisons (e.g., IM nail vs. screws); 10 Sampling issues (representativeness); 11 Role of registries

4. We used stakeholder comments and the Revised Research Agenda to develop a two-part prioritization activity for stakeholders to rate and rank 1.) hip fracture outcomes measurement issues and the best way to resolve them, and 2.) specific research questions and whether or not each could be addressed with a randomized clinical trial (RCT).

Research prioritization by stakeholders was accomplished with a two-part activity. The first part listed a set of potential consensus conference research agenda items. Stakeholders were asked to rate the importance of each issue on a 1 to 10 scale, with 10 being most important, and then rank the priority of each of 13-items with 1 being most important and 13 being of least importance. The second part of the activity listed a set of potential hip fracture research questions. Stakeholders were asked to rank the research questions, and indicate whether an RCT would be a good candidate research design to answer the question. The activity is shown in Figure C-1 below:

Figure C-1 Research prioritization activity for hip fracture outcomes stakeholders and experts

We explored various means of setting criteria for the prioritization exercise. We initially intended to use the Effective Health Care selection criteria. However, this proved to be off-target for this form of methods related research needs. Instead, the prioritization activity, as can be seen in Figure C-1, attempted to contextualize the activity by asking participants to think about a possible agenda for an invitation-only consensus conference on hip fracture research.

5. Activity results were tabulated; means and standard deviations are reported for X, Y and Z.

Prioritization activity results were tabulated and rank was calculated based on mean scores. Ties in rankings were allowed. Nonresponders were sent reminder emails. If another stakeholder was invited to participate in place of a nonresponder, the nonresponder was notified that his or her participation in the prioritization exercise was not required. At total of seven non-government stakeholders, and three government employees, responded to the activity.

6. Stakeholder feedback was solicited on ways to incentivize surgeons and researchers to adopt research recommendations, including future consensus conference results.

An email was distributed to all stakeholders asking for advice on how to incentivize researchers to improve study design quality. We provided a list of possible options that were generated by the investigators, based in part on stakeholder comments during general discussions on the stakeholder conference call. Stakeholders were asked to respond by email whether they agreed, dissented, or comments regarding the three options. They were also invited to make any other suggestions for incentivizing the field toward change.

The possible options listed were:

- Create a set of study design and outcome measurement recommendations, similar to CONSORT, for journals to adopt as a mandatory publication requirement,
- Encourage research funders to use a similar set of recommendations in writing RFPs, or scoring (bonus points?) submissions,
- Podium presentations by opinion leaders calling for adopting recommendations.