# List of Ongoing and Recently Published Studies

Table B-1 List of identified relevant studies from trial registries

Trial # (Registry) | Trial Name | Investigators Study Sponsor Collaborators
NCT01051830 (ClinicalTrials.gov) | Care model for hip fractured elderly persons with diabetes mellitus | (none listed) Chang Gung Memorial Hospital National Health Research Institutes, Taiwan
NCT00556842 (ClinicalTrials.gov) | Comparing total hip arthroplasty and hemi-arthroplasty on revision surgery and quality of life in adults with displaced hips fractures (HEALTH) | M. Bhandari, TA Eihnorn, MJ Heetveld NIAMS Hamilton Health Sciences, ZonMw: Netherlands, CIHR: Canada
NCT00557167 (ClinicalTrials.gov) | Evaluation of surgical fixation using alternative implants for the treatment of hip fractures (FAITH) | M Bhandari Canadian Institutes of Health Research NIH, Stichting Nuts Ohra
NCT00323232 (ClinicalTrials.gov) | Comparison of treatment outcomes in hip fractures surgiacally fixed with either a two or four hole device | PJ O’Brien University of British Columbia
NCT00491673 (ClinicalTrials.gov) | A prospective randomized trial of uncemented versus cemented hemiarthroplasty for displaced femoral neck fractures (HEMI04) (completed) | W Figved Ullevaal University Hospital Asker & Baerum Hospital
NCT00859378 (ClinicalTrials.gov) | Cemented vs non-cemented semiendoprosthesis in the treatment of proximal femoral fractures | (none listed) Kuopio University Hospital Finnish Foundation of Orthopedics and Traumatology
NCT00800124 (ClinicalTrials.gov) | Prospective randomized study on cemented versus non-cemented hemiarthroplasty in elderly with hip fractures | O Talsnes Sykehuset Innlandet HF Rikshospitalet University Hospital, Sykehuset Buskerud
NCT00306917 (ClinicalTrials.gov) | Prospective, randomized study of Summit Porocoat vs Summit DuoFix HA in cementless total hip arthroplasty | DA Fisher, JW Mesko, P Perona, SB Lowe, DL Pomeroy, N Reddy DePuy Orthopaedics
NCT00736684 (ClinicalTrials.gov) | Proximan femoral nail antirotation (PFNA) vs Gamma Nail 3 (Gamma3) for intramedullary nailing of unstable trochanteric fractures (PROGAINT-ES) | J Vaquero Martin AO Clinical Investigation and Documentation Synthes Inc.
NCT00595634 (ClinicalTrials.gov) | Intramedullary nailing for treatment of unstable intertrochanteric hip fracture outcome study (INTUIT) | G Brown Smith & Nephew Recon
NCT00621088 (ClinicalTrials.gov) | A prospective randomized multicenter study comparing the sliding hip screw and the InterTAN nail in trochanteric and subtrochanteric femoral fractures | K Matre Haukeland University Hospital
NCT00597779 (ClinicalTrials.gov) | Extramedullary vs intramedullary devices in the treatment of unstable intertrochanteric hip fractures | R Reindl McGill University Health Center Orthopaedic Trauma Association
NCT00664950 (ClinicalTrials.gov) | InterTAN IM nail versus sliding hip screw in geriatric fractures | D Sanders, D Bryant Lawson Health Research Institute Orthopaedic Research Foundation
NCT00829725 (ClinicalTrials.gov) | Comparison study of 3–4 screws internal fixation with multi-screw system Targon FN for femoral neck fracture | (none listed) Sheba Medical Center
NCT00555945 (ClinicalTrials.gov) | Re-evaluation of Gamma3 intramedullary nails in intertrochanteric hip fracture (REGAIN) | M Bhandari Hamilton Health Sciences Stryker Orthopaedics
NCT00317837 (ClinicalTrials.gov) | Bi-polar vs unipolar hemiarthroplasty for patients aged 70 years or above with a dislocated medial femoral neck fracture | M Lamm Northern Orthopaedic Division, Denmark
NCT00764153 (ClinicalTrials.gov) | Hemiarthroplasty or internal fixation for displaced femoral neck fractures—5 years follow up | JE Madsen Ullevaal University Hospital Norwegian Foundation for Health and Rehabilitation, Research Council of Norway
ACTRN12609000367246 (WHO Portal) | A randomized clinical trial of pain and mobility following cemented vs uncemented hemiarthroplasy in elderly patients with hip fracture | F Taylor Accident Compensation Corporation
ACTRN12608000162314 (WHO Portal) | Prospective randomized pilot study comparing the dynamic hip screw and intramedullary gamma nail regarding the treatment of intertrochanteric hip fracture | R. Molnar Unfunded
3R37AG009901-14S1 (RePORTER) | Sequelae of hip fracture in men: an epidemiologic study | J Magaziner University of Baltimore NIA
5R01AG029315-04 (RePORTER) | The epidemiology of bone strength and muscle composition after hip fracture in men | J Magaziner University of Baltimore NIA

Table B-2 Randomized clinical trials published May 2008 to July 2010

Author, Year, Country | Comparison | Fracture Pattern, Patient Population | Patient N | Randomization Scheme | Outcomes | Results
Femoral Neck: Displaced/Not Displaced
Leonardsson, 2010^1^ Sweden | Arthroplasty vs. IF: results at 10 years follow-up *2 year results published by Rogmark et al. in 2002 (JBJS-Br) | displaced femoral neck fractures: Garden 3 or 4; age 70+, 1995–97 Exclude: confused, bed-ridden, RA, not community, fracture older than 2 days | N=450 IF: 217 arthro: 192 | 41 patients excluded for various reasons after randomization “by sealed, numbered opaque envelopes” | Mortality, device failure, and a “standardized questionnaire that assessed social and medical factors, as well as walking ability” 5 years: by mail. 10 years: 53/96 had exam and x-rays | Failures: 45.6% in IF vs. 8.8% in replacement. Most common reasons for “salvage revision” in IF group were nonunion and AVN. Mortality same: 75% at 10 yrs. Pt-reported pain and function similar in both groups at 5, 10 yrs.
Figved, 2009^2^ Norway | Cemented vs. uncemented hemiarthroplasty (both bipolar) | displaced femoral neck fractures, age 70+ | N=220 c: 112 un:108 | Two sites randomized separately using a computer random number generator with permuted blocks of five | HHS, Barthel Index, EQ-5D | Barthel index and EQ-5D scores were similar across groups. Rates of complications and mortality similar.
Macaulay, 2008^3^ USA | hemiarthroplasty vs. THA (DFACTO) | displaced femoral neck fractures, previously independent | n=40 | “..opaque sealed envelope technique ”. Blocked randomization, 5 sites | 6, 12, 24 mo: SF-36, WOMAC, HHS, timed up & go | At 24 months, THA had significantly less pain on SF36 and scored better on SF-36 MH subscale. THA had superior WOMAC.
Extracapsular/Stable and Unstable Intertrochanteric and Subtrochanteric
Barton, 2010^4^ UK | Long Gamma Nail vs. Sliding Hip Screw (4-hole plate) | AO/OTA 31-A2 (Intertrochanteric), Ages 42–99. Half of patients had “reduced mental capacity” by Mini-mental score <10 Exclude: prior or pathologic, reverse oblique, surgeon decided not to enroll | N=210; LGN:100 SHS:110 | “Randomization was carried out with the use of sealed envelopes generated by a medical statistician. One envelope was selected and opened at daily trauma meeting”. Sample size est. was 220; 300 envelopes were generated but only 210 enrolled: groups were unbalanced on mental status | Primary: reoperation by 1 year; secondary: EuroQoL 5D; mobility and residence (at admit and 1 year) used 5 point scale | No significant differences in reoperation at 1 year or EQ-5D, any secondary outcomes. No differences in mortality after correction for the mini-mental score (more LGN patients had reduced mental scores-see randomization). Third generation LGN (current)

DHS=Dynamic hip screw, IF=Internal fixation, IMN=Intramedullary nail, NR=Not reported, RCT=Randomized controlled trial, SHS=Sliding hip screw, THA=Total hips arthroplasty

Table B-3 Observational trials published May 2008 to July 2010

Author Year country | Study Aim | Patient N follow-up | Patient population, fracture type | Outcomes | Surgical treatment | Site | Results
Samuelsson, 2009^1^ Sweden | Analyze outcomes after hip fracture with respect to gender and cognitive function | N=2,134 2 years | consecutive patients in 2003. All nonpathologic fractures age 25–103 (12% of patients were < age 69) intra- vs. extracapsular fractures, no subtypes | By gender and cognitive status: Mortality, residence, walking ability and activities of daily living (ADLs) were analyzed at baseline, 4 and 24 months. Assessed by phone or postal questionnaire; mortality by proxy or hospital register | internal fixation or prosthesis | 4 university hospitals in Stockholm | Women were older, more often living alone and had poorer walking ability at baseline. Women with intracapsular fractures were significantly more often treated with arthroplasty. Men had higher risk for losing walking ability and death only among men with cognitive impairment. Cognitive function was the most important factor in regaining prefracture function and returning to own home

Table B-4 Systematic reviews and meta-analyses published May 2008 to July 2010

First Author, Year | Title Fracture Pattern Patient Population | # of Studies Patient N Hip N | Devices | Outcomes Addressed | Reported Results
Femoral Neck: Displaced/Not Displaced
Hopley 2010^1^ Searched 1966 to March 2010 | Primary total hip arthroplasty versus hemiarthroplasty for displaced intracapsular hip fractures in older patients: systematic review. Patient age > 60 years | 4 RCTs, 3 quasirandomized trials, 8 retrospective cohort studies N=1890 | THA vs. hemiarthroplasty | Reoperations, mortality, complications, function, QoL | THA may lead to lower reoperation rates and better functional outcomes compared with hemiarthroplasty. However, reoperation effect was mainly driven by studies without concealed treatment allocation. Study heterogeneity precluded definitive statements; further research was recommended.
Goh 2009^2^ Searched 1966 to February 2006 | Meta-analysis comparing total hip arthroplasty with hemi-arthroplasty in the treatment of displaced neck of femur fracture | 3 RCTs N=407 | THA vs. hemiarthroplasty | Primary: revision hip surgery. Secondary: mortality, pain, hip function and mobility | No significant differences mortality at any time point (1, 2, 3 and 13 years). THA had significantly less pain at 1 year but not at 2 years. No significant differences in dislocation at any time point.
Wang 2009^3^ Searched 1979 to May 2008 | Arthroplasty or internal fixation for displaced femoral neck fractures: which is the optimal alternative for elderly patients? A meta-analysis Garden 3 or 4 | 20 RCTs and quasirandomized trials (N=3,109). 10 RCTs (N=1,477) had complications at 2 years. 2 RCTs had complications at 5 years (N=380) | All types of internal fixation versus arthroplasty (THA or hemi, including uni-and bipolar) | Mortality, pain, revision surgery, surgical and medical complications | No significant differences mortality at any time point. No differences in pain at 1 year. Arthroplasty had higher risk of deep infection, and that was associated with the need for reoperation. Arthroplasty had significantly fewer reoperations at 1, 2 and 5 years.
Extracapsular/Stable and Unstable Intertrochanteric and Subtrochanteric
Bhandari, 2009^5^ Searched 1969 to January 2006 | Gamma nails revisited: Gamma nails versus compression hip screws in the management of intertrochanteric fractures of the hip: a meta-analysis | 20 RCTs N=3,464 | Gamma nail vs. sliding hip screw | Femoral shaft fracture | Risk of femoral shaft fracture related to Gamma nails appears to be decreasing over time. Based on 352 patients from 2005, authors concluded that risk was no longer significant compared with sliding hip screw procedures.
Parker 2008^6^ Searched 1966 to June 2007 | Gamma and other cephalocondylic intramedullary nails versus extramedullary implants for extracapsular hip fractures in adults. | 36 RCTs and quasi N= (22 compared GN vs. SHS in 3,871 patients) | intramedullary nails versus extramedullary implants, multiple types | Operative details, fracture fixation complications, post-op complications, anatomical restoration, mortality, pain, mobility, failure to return to pre- fracture residential status | Update of 2005. Sliding hip screw superior for trochanteric fractures compared to IMN due to lower device complication rates. Functional outcomes, mortality and postoperative complications were similar. Further research required if intramedullary nails have advantages for other fracture types (example: subtrochanteric) or if different IMNs produce similar results.
Kuzyk, 2009^7^ Searched through June 2007 | Minimally Invasive Hip Fracture Surgery: Are Outcomes Better? intertrochanteric fractures | 14 RCTs N=not stated (Table 1 total is 2,099) | Minimally-invasive plating, nailing or external fixation vs. SHS; many implants | Mortality, fixation failure, transfusion need, operative time | Transfusion was significantly lower in minimally-invasive group. No significant differences for other outcomes, including mortality.
Panesar, 2008^8^ Searched 1995–2006 | The percutaneous compression plate versus the dynamic hip screw: a meta-analysis head to head trials (1995–2006) | ? | PCCP versus DHS | Primary: mortality at one year. Secondary: perioperative factors | Decreased trend in early mortality in PCCp group (p=0.51). “Similar trends found for other outcomes.”
Jiang 2008^4^ Searched ? | No advantages of Gamma nail over sliding hip screw in the management of peritrochancteric hip fractures: a meta-analysis of randomized controlled trials | 11 RCTs N=1,344 | Gamma nail vs. sliding hip screw | Mortality, cut- out, non- union, re- operation, wound infection, intra- operative fractures of femur, blood loss or surgical time | There were no significant differences between groups on any outcomes. Authors concluded there were no obvious advantages of Gamma nails over sliding hip screw fixation.
Subtrochanteric
Kuzyk, 2009^9^ Searched through June 2007 | Intramedullary versus extramedullary fixation for subtrochanteric femur fractures Included intertroch with subtroch extension. | 12 studies: N=NR (Table 1 total = 691) Three level I studies were used to calculate a pooled relative risk for failure of fixation | | Fixation failure, operative time, blood loss, intraoperative complications, postoperative medical complications, transfusion need, wound complications, nonunion, length of hospital stay, and functional recovery | Grade B evidence that operative time and fixation failure are reduced with the use of intramedullary implants for subtrochanteric fractures. “Studies rarely provided information on preoperative medical or functional status.” Only one level 1 study reported significantly better walking ability at 4 weeks in the IMN group, but no difference at 4 or 12 months.

DHS=Dynamic hip screw, IF=Internal fixation, IMN=Intramedullary nail, NR=Not reported, RCT=Randomized controlled trial, SHS=Sliding hip screw, THA=Total hips arthroplasty

## References for Table B-2

1 Leonardsson O, Sernbo I, Carlsson A, et al. Long-term follow-up of replacement compared with internal fixation for displaced femoral neck fractures: results at ten years in a randomised study of 450 patients. J Bone Joint Surg Br. Mar. 2010;92(3):406-412. [pmid: 20190313].
2 Figved W, Opland V, Frihagen F, et al. Cemented versus uncemented hemiarthroplasty for displaced femoral neck fractures. Clin Orthop Relat Res. Sep. 2009;467(9):2426-2435. [pmid: 19130162].
3 Macaulay W, Nellans KW, Garvin KL, et al. Prospective randomized clinical trial comparing hemiarthroplasty to total hip arthroplasty in the treatment of displaced femoral neck fractures: winner of the Dorr Award. J Arthroplasty. Sep. 2008;23(6 Suppl 1):2-8. [pmid: 18722297].
4 Barton TM, Gleeson R, Topliss C, et al. A comparison of the long gamma nail with the sliding hip screw for the treatment of AO/OTA 31-A2 fractures of the proximal part of the femur: a prospective randomized trial. J Bone Joint Surg Am. Apr. 2010;92(4):792-798. [pmid: 20360500].

## References for Table B-3

1 Samuelsson B, Hedstrom MI, Ponzer S, et al. Gender differences and cognitive aspects on functional outcome after hip fracture--a 2 years’ follow-up of 2,134 patients. Age Ageing. Nov. 2009;38(6):686-692. [pmid: 19767316].

## References for Table B-4

1 Hopley C, Stengel D, Ekkernkamp A, et al. Primary total hip arthroplasty versus hemiarthroplasty for displaced intracapsular hip fractures in older patients: systematic review. BMJ. 2010;340:c2332. [pmid: 20543010].
2 Goh SK, Samuel M, Su DH, et al. Meta-analysis comparing total hip arthroplasty with hemiarthroplasty in the treatment of displaced neck of femur fracture. J Arthroplasty. Apr. 2009;24(3):400-406. [pmid: 18701252].
3 Wang J, Jiang B, Marshall RJ, et al. Arthroplasty or internal fixation for displaced femoral neck fractures: which is the optimal alternative for elderly patients? A meta-analysis. Int Orthop. Oct. 2009;33(5):1179-1187. [pmid: 19343344].
4 Jiang SD, Jiang LS, Zhao CQ, et al. No advantages of Gamma nail over sliding hip screw in the management of peritrochanteric hip fractures: a meta-analysis of randomized controlled trials. Disabil Rehabil. 2008;30(7):493-497. [pmid: 17852303].
5 Bhandari M, Schemitsch E, Jonsson A, et al. Gamma nails revisited: gamma nails versus compression hip screws in the management of intertrochanteric fractures of the hip: a meta-analysis. J Orthop Trauma. Jul. 2009;23(6):460-464. [pmid: 19550235].
6 Parker MJ, Handoll HH. Gamma and other cephalocondylic intramedullary nails versus extramedullary implants for extracapsular hip fractures in adults. Cochrane Database Syst Rev. 2008;3:CD000093. [pmid: 18646058].
7 Kuzyk PR, Guy P, Kreder HJ, et al. Minimally invasive hip fracture surgery: are outcomes better?. J Orthop Trauma. Jul. 2009;23(6):447-453. [pmid: 19550233].
8 Panesar SS, Mirza S, Bharadwaj G, et al. The percutaneous compression plate versus the dynamic hip screw: a meta-analysis. Acta Orthop Belg. Feb. 2008;74(1):38-48. [pmid: 18411600].
9 Kuzyk PR, Bhandari M, McKee MD, et al. Intramedullary versus extramedullary fixation for subtrochanteric femur fractures. J Orthop Trauma. Jul. 2009;23(6):465-470. [pmid: 19550236].