# Search Strategy for Recently Published and Ongoing Studies

Medline was searched from 2008-present (July, 2010) for randomized clinical trials, systematic reviews, meta-analyses, and observational studies, to determine if publications subsequent to the 2009 Minnesota EPC report partially filled the previously-identified knowledge gaps. The search strategy used in the original report was replicated. This search included a list of terms intended to identify all research publications associated with intertrochanteric/subtrochanteric and subcapital hip fractures. Searches for trials were further limited by terms to identify types of surgical implant interventions. We also manually searched reference lists from relevant systematic reviews. Publications were assessed for relevance through dual review at the title/abstract level; applicable studies were retrieved, reviewed, and matched to one or more existing research gap areas.

We also searched ClinicalTrials.gov (http://clinicaltrials.gov), the WHO International Clinical Trials Registery platform (ICTRP) (http://www.who.int/ictrp/en/), and the NIH Research Portfolio Online Reporting Tool (RePORT) (http://projectreporter.nih.gov/reporter.cfm) web-based trial registries for relevant ongoing studies. Searches were conducted using simple search terms such as “hip fracture.” Trial records were reviewed for relevance based on patient population, age 50 and older with a nonpathologic fracture that resulted from low energy trauma, and fracture type. All types of femoral neck or intracapsular fractures were included. Applicable studies were reviewed and matched to one or more existing research gap area.