# Abbreviations

EPC: Evidence-based Practice Center
RCT: Randomized controlled trial