# Results

## Needs Identified in CER

From the comparative effectiveness review (CER), the project team organized a list of research gaps to present to the stakeholder group. These needs were initially organized by topic based and methods based research gaps. The project team further characterized the research needs topically and presented in an outline format (Appendix C) which was distributed to the stakeholders along with a summary table of ongoing research. (Appendix B)

## Engagement of Stakeholders

Stakeholders broadly represented clinical, research, and advocacy perspectives in noncyclic chronic pelvic pain (CPP). Of the 12 individuals who agreed to participate as stakeholders, five served previously as a Key Informant or a Technical Expert Panel member for the CPP CER. After agreeing to participate, one stakeholder did not respond to scheduling requests for the initial conference call. The participating panel consisted of a total of eleven stakeholders including clinical researchers with expertise in CPP, physical therapists, and a patient advocate.

All stakeholders provided statements disclosing any conflict of interests. Three stakeholders documented participation as board members in professional societies dedicated to conditions of pelvic pain. There were no disclosures that were judged to be significant enough to preclude participation in the project.

### Conference Calls

Eleven stakeholders participated in one of two conference calls. Stakeholders were asked to comment on the list of research gaps from the CER and discuss research issues pertinent to the topic. The moderator (SR) encouraged call participants to propose research needs related to noncyclic CPP that were not captured by the CER-generated list. Appendix D includes a summary of discussion from the initial stakeholder call. From these calls, we generated an expanded list of 63 research needs; 28 were derived from the stakeholders and 35 were derived from the CER (Appendix E).

### Round One Prioritization

We presented the expanded list of research needs to stakeholders in an initial survey. (Appendix F) We organized questions broadly by area of focus and present them by category in no particular order. We asked stakeholders to rate the research needs according to perceived degree of importance using a 5-point Likert scale. Six of the 12 stakeholders completed the survey. Table 3 lists the highest rated items (i.e., research needs with an average score of at least 4.3) identified via the initial rating survey.

Table 3 Highest rated research needs^a^

Rank | Research Need
1. | Conduct studies on patient education.
2. | Clinician education on communication of laparoscopy results to patients.
3. | Determine which patients are likely to benefit from surgery.
4. | Develop standardized scales to assess quality of life for patients with noncyclic chronic pelvic pain.
5. | Develop standardized diagnostic criteria.
6. | Standardize diagnostic evaluations including history and physical.
7. | Collect and analyze data to inform health care utilization and cost relationship.
8. | Determine the accuracies of individual and combined diagnostic tests.
9. | Assess the impact of noncyclic chronic pelvic pain on the use of health services.
10. | Determine the role of musculoskeletal evaluations on resource use.
11. | Conduct studies on self-management.
12. | Standardize optimal surgical outcomes including followup interval (e.g., long-term outcomes).
13. | Determine the overall role of surgery.
14. | Determine optimal followup to assess outcomes following surgical interventions.
15. | Determine the role of idiopathic causes in the pathophysiology of noncyclic chronic pelvic pain.
16. | Identify risk associations and women at risk for developing noncyclic chronic pelvic pain.
17. | Document the treatment effect of diagnostic laparoscopy.
18. | Determine the direct and indirect costs that contribute to health care expenditures and economic impact.
19. | Conduct studies on physiotherapy.
20. | Conduct studies on cognitive behavior therapy.
21. | Conduct studies on provider education.
22. | Conduct studies on the management of patients who have failed pharmacologic treatment.
23. | Determine the optimal timing of surgical intervention.
24. | Determine the role of surgical or pathologic diagnosis on treatment outcomes.
25. | Characterize and document the distribution and prevalence of comorbidities and conditions associated with noncyclic chronic pelvic pain.
26. | Identify the most cost effective diagnostic and management strategies.
27. | Characterize chronic pelvic pain subtypes, including the significance of differentiation between cyclic and noncyclic.
28. | Characterize the distribution of symptom components (e.g., dyspareunia, dysmenorrhea, etc.) of noncyclic chronic pelvic pain.
29. | Characterize the role of the patient-provider relationship on surgical outcomes.
30. | Determine the role of condition-specific causes (e.g., endometriosis, pelvic adhesions, pelvic congestion, etc.) in the pathophysiology of noncyclic chronic pelvic pain.
31. | Determine patient dissatisfaction with care.

Notes:

a Items with an average rating of 4.3 or higher

### Round Two Prioritization

In the second survey we asked stakeholders to score each of the 31 high priority needs across the following selection criteria from the AHRQ Prioritization Criteria Method (PiCMe)37 using a 1 (low) to 5 (high) point scale:

- Potential for new knowledge
- Potential for significant health impact
- Potential to reduce inappropriate variation in clinical practices
- Potential for significant economic impact
- Potential risk from inaction
- Potential to address inequities

We sent a link to the second survey approximately 2 weeks after the close of the first survey. The survey was open for one week, at which point five stakeholders had completed the survey. We sent an email reminder and extended the survey deadline by 3 business days. In total, seven stakeholders completed the second survey. Results were analyzed based on the responses received. We did not further query the nonresponders.

We tallied the scores for each question on each criterion to determine an overall score. We considered those questions with an overall score of at least 4.0 (n=6) to comprise the top tier of research needs (Table 4).

Table 4 Top-tier research needs^a^

Score | Research Need
4.31 | Determine which patients are likely to benefit from surgery.
4.22 | Develop standardized diagnostic criteria.
4.16 | Identify risk associations and women at risk for developing noncyclic chronic pelvic pain.
4.15 | Determine the overall role of surgery.
4.04 | Conduct studies on the management of patients who have failed pharmacologic treatment.
4.03 | Identify the most cost effective diagnostic and management strategies.

Notes:

a Research needs with an average score of 4.0 or higher on the second survey

We also extracted items with an overall score of 3.75–3.99 (n=9) to comprise the second tier of research needs (Table 5). Of note, the scores were all very close, and no set of recommended studies should be considered low priority. The rating provides a relative measure; all of the research questions are important, but a subset comprises a priority set that should be addressed first. The results from the second survey are presented in Appendix H and a rank ordered list of all research needs is presented in Appendix I.

Table 5 Second-tier research needs^a^

Score | Research Need
3.98 | Conduct studies on cognitive behavior therapy.
3.94 | Standardize diagnostic evaluations including history and physical.
3.90 | Standardize optimal surgical outcomes including followup interval (e.g., long-term outcomes).
3.86 | Determine the accuracies of individual and combined diagnostic tests.
3.84 | Conduct studies on patient education.
3.82 | Determine patient dissatisfaction with care.
3.80 | Document the treatment effect of diagnostic laparoscopy.
3.80 | Conduct studies on provider education.
3.78 | Assess the impact of noncyclic chronic pelvic pain on the use of health services.

Notes:

a Research needs with an average score of 3.75–3.99 on second survey

### Research Design Considerations

The investigative team reviewed and discussed the top and second tier research needs in light of the CER, ongoing research, and initial discussions with the stakeholders. The lead investigator developed suggestions for potential study design for each of the top-tier research needs. We also highlight methodologic challenges and issues specific to each research need that may encumber efforts to transform the question into a practical research agenda (Table 6). The top-tier research needs underscore the lack of findings reported in the initial CER while others, such as diagnosis or cost effectiveness, are more general and indirectly related to the CER, although still partially within the scope of the CER.

Table 6 Top-tier research needs: PICOTS, study designs, considerations, and relationship to CER

Research Need Source | PICOTS Element(s) | Potential Study Designs and Considerations | Relationship to CER
Determine which patients are likely to benefit from surgery. CER | P: Women with noncyclic CPP I: Surgical C: Surgical or nonsurgical O: Symptom resolution; QOL T: >12 months S: Community and clinic | Diagnostic and treatment RCT with subpopulation analysis and/or strict inclusion criteria of a well-defined population; - Comparison of treatment may be surgery A vs. surgery B or surgery vs. nonsurgical intervention or surgery vs. sham-surgery.; - Standardizing surgical interventions can be problematic. Surgical care is a highly technical, complex process and requires the coordination of many individuals and systems. | Addressed specifically by KQ2 and KQ3 of the CER. Of seven studies addressing KQ2, one was assessed as good, one as fair, and five as poor quality. No studies addressing KQ3 were identified.
Develop standardized diagnostic criteria. CER | P: Women with pelvic pain I: Diagnostic test/criteria C:Diagnostic test/criteria O: Diagnostic accuracy T: N/A S: Clinic | Validation study of consensus-developed diagnostic criteria, in the light of systematic reviews (international, multisite, between-subjects design); - Requires an international effort. (Comparison process: Rome I, II, III criteria for diagnostic criteria for IBS and validation, diagnostic criteria for headache, complex regional pain syndrome, and psychiatric disorders).; - Challenge precluding a RCT is that there is no gold standard diagnostic test. | Addressed indirectly by all KQs of the CER. Across all studies for therapeutic interventions there were large inconsistencies noted in the CER for diagnostic criteria. May benefit from a systematic review to assess status of existing, if any, diagnostic criteria for CPP.
Identify risk associations and women at risk for developing noncyclic chronic pelvic pain. CER | P: Women with and without noncyclic CPP I: N/A C: N/A O: Noncyclic CPP diagnosis and diagnosis of an at-risk comorbid condition T: >12 months S: Community and clinic | Observational study: prospective cohort (longitudinal) or case-control study; - Cohort study would need to be large and long term. Expensive because development of CPP “rare”: a solution would be to add to a larger prefunded cohort study.; - Case-control studies can be very efficient; but only one outcome per study; threats to validity include recall bias, control selection, and response rates.; - Other challenges include the difficulty imposed by confounding (mixing of effects) and risk factor interaction (synergy, antagonism). | Addressed partially by KQ1 of the CER. Additional systematic review may be needed to identify studies not included within the scope of CER.
Determine the overall role of surgery. Stakeholders | P: Women with noncyclic CPP I: Surgical C: Surgical or nonsurgical O: Symptom resolution; QOL T: >12 months S: Community and clinic | Prospective cohort; - Common critiques are that observational research studies systematically overestimate treatment effect and are limited by unavoidable confounding and bias. To account for these potential limitations, investigators can use several statistical and methodological techniques, including regression, stratification, and patient matching.; - Standardizing surgical interventions can be problematic. Surgical care is a highly technical, complex process and requires the coordination of many individuals and systems. | Addressed specifically by KQ2 of the CER. Of seven studies addressing KQ2, one was assessed as good, one as fair, and five as poor quality.
Conduct studies on the management of patients who have failed pharmacologic treatment. CER | P: Women with noncyclic CPP that have failed prior treatment I: Surgical or nonsurgical C: Surgical, nonsurgical, no treatment O: Symptom resolution; QOL T: >6 months S: Clinic | RCT (optimal design for therapy should be placebo-controlled, double-blind, parallel group, and randomized to treatment allocation); - Well-defined inclusion and exclusion criteria will be necessary, to define “failure” for every pharmacologic treatment.; - Challenges include high placebo response rate, fluctuating symptoms, heterogeneous and complex mechanisms, avoiding bias, contamination by over-the-counter treatments or drugs for other conditions, avoiding harm, duration of the treatment intervention, frequency of treatment, and difficulty blinding the intervention. | Addressed specifically by KQ5 of the CER; however, no studies addressing KQ5 were identified in the CER.
Identify the most cost effective diagnostic and management strategies. CER | P: Women with noncyclic CPP I: Diagnostic test, surgical or nonsurgical therapy C: Diagnostic test, surgical or nonsurgical therapy O: Resource utilization outcomes T: >12 months S: Clinic | Decision analytic modeling comparison of two or more alternatives or designed within a clinical trial (RCT: running in parallel with the main study is a prospective economic analysis); - Not appropriate for placebo-controlled or sham-surgery as comparator, because the placebo arm limits generalizability to clinical practice. | Not addressed by KQs of the CER. Consider systematic reviews to identify studies focused on diagnosis of CPP.

Abbreviations: CER=comparative effectiveness review; CPP=chronic pelvic pain; IBS=irritable bowel syndrome; KQ=Key Question; N/A=not applicable; PICOTS=population, intervention, comparator, outcome, timing, setting; QOL=quality of life; RCT=randomized controlled trial.