# References

1 Agency for Healthcare Research and Quality. Noncyclic Chronic Pelvic Pain Therapies for Women Comparative Effectiveness. 2012. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=931&pageaction=displayproduct. Accessed July 6, 2012.
2 Williams RE, Hartmann KE, Steege JF. Documenting the current definitions of chronic pelvic pain: implications for research. Obstet Gynecol. Apr. 2004;103(4):686-91. [pmid: 15051560].
3 ACOG Practice Bulletin No. 51. Chronic pelvic pain. Obstet Gynecol. Mar. 2004;103(3):589-605. [pmid: 14990428].
4 Stones W, Cheong Ying C, Howard Fred M, et al. Interventions for treating chronic pelvic pain in women. Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2005.
5 Leserman J, Zolnoun D, Meltzer-Brody S, et al. Identification of diagnostic subtypes of chronic pelvic pain and how subtypes differ in health status and trauma history. Am J Obstet Gynecol. Aug. 2006;195(2):554-60. discussion 60–1. [pmid: 16769027].
6 Howard FM. Chronic pelvic pain. Obstet Gynecol. Mar. 2003;101(3):594-611. [pmid: 12636968].
7 Howard Fred M. Evaluation of chronic pelvic pain in women. UpToDate 2011. April. 9. 2010.
8 Stratton P, Sinaii N, Segars J, et al. Return of chronic pelvic pain from endometriosis after raloxifene treatment: a randomized controlled trial. Obstet Gynecol. Jan. 2008;111(1):88-96. [pmid: 18165396].
9 Swank DJ, Swank-Bordewijk SC, Hop WC, et al. Laparoscopic adhesiolysis in patients with chronic abdominal pain: a blinded randomised controlled multi-centre trial. Lancet. Apr. 12. 2003;361(9365):1247-51. [pmid: 12699951].
10 Daniels J, Gray R, Hills RK, et al. Laparoscopic uterosacral nerve ablation for alleviating chronic pelvic pain: a randomized controlled trial. JAMA. Sep. 2. 2009;302(9):955-61. [pmid: 19724042].
11 Abbott JA, Jarvis SK, Lyons SD, et al. Botulinum toxin type A for chronic pain and pelvic floor spasm in women: a randomized controlled trial. Obstet Gynecol. Oct. 2006;108(4):915-23. [pmid: 17012454].
12 Ling FW. Randomized controlled trial of depot leuprolide in patients with chronic pelvic pain and clinically suspected endometriosis. Pelvic Pain Study Group Obstet Gynecol. Jan. 1999;93(1):51-8. [pmid: 9916956].
13 Karp BI, Sinaii N, Nieman LK, et al. Migraine in women with chronic pelvic pain with and without endometriosis. Fertil Steril. 2010. Dec. 8. [pmid: 21145540].
14 Lamvu G, Williams R, Zolnoun D, et al. Long-term outcomes after surgical and nonsurgical management of chronic pelvic pain: one year after evaluation in a pelvic pain specialty clinic. Am J Obstet Gynecol. Aug. 2006;195(2):591-8. discussion 8–600. [pmid: 16729951].
15 Carlson KJ, Miller BA, Fowler FJ Jr. The Maine Women’s Health Study: II. Outcomes of nonsurgical management of leiomyomas, abnormal bleeding, and chronic pelvic pain. Obstet Gynecol. Apr. 1994;83(4):566-72. [pmid: 8134067].
16 Zondervan KT, Yudkin PL, Vessey MP, et al. Prevalence and incidence of chronic pelvic pain in primary care: evidence from a national general practice database. Br J Obstet Gynaecol. Nov. 1999;106(11):1149-55. [pmid: 10549959].
17 The International Pelvic Pain History and Physical Form. 2008. www.pelvicpain.org/resources/handpform.aspx.
18 Dworkin RH, Turk DC, Wyrwich KW, et al. Interpreting the clinical importance of treatment outcomes in chronic pain clinical trials: IMMPACT recommendations. J Pain. Feb. 2008;9(2):105-21. [pmid: 18055266].
19 Gallagher RM. Biopsychosocial pain medicine and mind-brain-body science. Phys Med Rehabil Clin N Am. Nov. 2004;15(4):855-82. vii. [pmid: 15458757].
20 Hyams JS. Irritable bowel syndrome, functional dyspepsia, and functional abdominal pain syndrome. Adolesc Med Clin. Feb. 2004;15(1):1-15. [pmid: 15272253].
21 Ong KS, Keng SB. The biological, social, and psychological relationship between depression and chronic pain. Cranio. Oct. 2003;21(4):286-94. [pmid: 14620702].
22 Turk DC, Okifuji A. Psychological factors in chronic pain: evolution and revolution. J Consult Clin Psychol. Jun. 2002;70(3):678-90. [pmid: 12090376].
23 Grace VM. Pitfalls of the medical paradigm in chronic pelvic pain. Baillieres Best Pract Res Clin Obstet Gynaecol. Jun. 2000;14(3):525-39. [pmid: 10962640].
24 Heyman J, Ohrvik J, Leppert J. Distension of painful structures in the treatment for chronic pelvic pain in women. Acta Obstet Gynecol Scand. 2006;85(5):599-603. [pmid: 16752240].
25 Ghaly AFF. The psychological and physical benefits of pelvic ultrasonography in patients with chronic pelvic pain and negative laparoscopy. A random allocation trial. Journal of Obstetrics & Gynaecology. 1994;14:269-71.
26 Peters AA, van Dorst E, Jellis B, et al. A randomized clinical trial to compare two different approaches in women with chronic pelvic pain. Obstet Gynecol. May. 1991;77(5):740-4. [pmid: 1826544].
27 Johnson NP, Farquhar CM, Crossley S, et al. A double-blind randomised controlled trial of laparoscopic uterine nerve ablation for women with chronic pelvic pain. BJOG. Sep. 2004;111(9):950-9. [pmid: 15327610].
28 Palomba S, Russo T, Falbo A, et al. Laparoscopic uterine nerve ablation versus vaginal uterosacral ligament resection in postmenopausal women with intractable midline chronic pelvic pain: a randomized study. Eur J Obstet Gynecol Reprod Biol. Nov. 2006;129(1):84-91. [pmid: 16442203].
29 Mathias SD, Kuppermann M, Liberman RF, et al. Chronic pelvic pain: prevalence, health-related quality of life, and economic correlates. Obstet Gynecol. Mar. 1996;87(3):321-7. [pmid: 8598948].
30 Turner JA, Deyo RA, Loeser JD, et al. The importance of placebo effects in pain treatment and research. JAMA. May. 25. 1994;271(20):1609-14. [pmid: 7880221].
31 Andrews J. Vulvodynia management: an evidence-based approach. J Clin Outcomes Manage. 2010;17(5):225-38.
32 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. Feb. 1. 1995;273(5):408-12. [pmid: 7823387].
33 Moseley JB, O’Malley K, Petersen NJ, et al. A controlled trial of arthroscopic surgery for osteoarthritis of the knee. N Engl J Med. Jul. 11. 2002;347(2):81-8. [pmid: 12110735].
34 Robinson KA, Saldanha IJ, McKoy NA. Development of a framework to identify research gaps from systematic reviews. J Clin Epidemiol. Dec. 2011;64(12):1325-30. [pmid: 21937195].
35 Agency for Healthcare Research and Quality. Future Research Needs - Methods Research Series. 2010. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=521. Accessed July 6, 2012.
36 Harris PA, Taylor R, Thielke R, et al. Research electronic data capture (REDCap)--a metadata-driven methodology and workflow process for providing translational research informatics support. J Biomed Inform. Apr. 2009;42(2):377-81. [pmid: 18929686].
37 Agency for Healthcare Research and Quality. Prioritization Criteria Methodology for Future Research Needs Proposals Within the Effective Health Care Program. 2010. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=964&pageaction=displayproduct. Accessed July 6, 2012.