# Methods

In the Agency for Healthcare Research Quality (AHRQ) Future Research Needs Methods Report, Robinson et al.34 define a research gap as a topic or area for which missing or inadequate information limits the ability of reviewers to reach a conclusion for a given question. This is distinguished from a research need, which they define as a gap that limits the ability of health care decisionmakers (e.g., patients, physicians, policymakers, etc.) from making decisions. The report further notes that a research gap may not be a research need if filling the gap would not be of use to stakeholders that make decisions in health care.35 Table 1 outlines the methods we used to identify and prioritize research needs. We expand on the table’s brief description in each of the following sections.

Table 1 Summary of steps for developing future research needs

| Approach to Evidence Gap Identification
1. | Generate preliminary list of research gaps based on findings of the CER
2. | Form stakeholder workgroup with representatives from advocacy organizations, provider community, research community, and funding agencies
3. | Locate ongoing trials and other funded research
4. | Conduct conference call with stakeholders to refine initial list of evidence gaps
| Approach to Prioritization and Stakeholder Engagement for Prioritization
5. | Invite stakeholders to rate perceived importance of individual research gaps
6. | Cull list of research needs based on stakeholder voting
7. | Invite stakeholders to prioritize research needs using modified EHC selection criteria
| Approach to Research Question Development and Considerations for Potential Research Designs
8. | Determine potential study designs to address final list of research needs
9. | Obtain stakeholder input on the draft research needs report
10. | Finalize research needs report

Abbreviations: CER=comparative effectiveness review; EHC=Effective Health Care Program

## Identification of Evidence Gaps

We identified evidence gaps that limited conclusions about each Key Question from the discussion and future research sections of the comparative effectiveness review (CER). One investigator extracted research gaps from the review. A senior investigator then reviewed the list for accuracy and completeness and added gaps as appropriate.

### Identification of Ongoing Research

To characterize the most recent evidence and current research, we updated the literature searches used in the CER and searched registries and other sources for ongoing research trials that have not yet published study results.35 To identify currently funded or recently completed research studies examining treatment of chronic pelvic pain in women or prevalence of comorbidities in women with chronic pelvic pain (CPP) (Appendix B) we conducted searches of U.S. government resources (ClinicalTrials.gov, NIH Reporter), international trial registries (e.g. Current Controlled Trials), and other potential funding sources such as relevant associations and organizations (e.g. American Academy of Family Physicians, American Association of Birth Centers; America’s Health Insurance Plans, International Pelvic Pain Society). Our searches were broad, employing the use of the keywords “chronic pelvic pain,” scanning retrieved items to identify relevant studies examining CPP treatment or comorbidity prevalence in women. We consulted the methods outlined in the future research needs methods series35 to confirm that we searched the key sources of information for current research.

## Engagement of Stakeholders, Researchers, and Funders

We sought to convene a group of stakeholders broadly representative of research, clinical care, patients, and funders to provide input on research gaps. We generated lists of potential stakeholders via a review of potential Technical Expert Panel members and Key Informants for the CER, review of investigators in studies included in the CER, review of advocacy and other agencies relevant to CPP, and through consultation with our Task Order Officer. We invited potential stakeholders by email, briefly describing the project purpose and scope and obtained voluntary consent forms from each individual agreeing to participate. To assess potential conflicts, we asked participants to review and complete the standard AHRQ conflict of interest disclosure form. We forwarded the completed forms to the Task Order Officer for review prior to the first scheduled conference call.

As the stakeholder group was largely comprised of individuals with many professional and academic roles, we anticipated that lack of time would contribute to a moderate level of attrition. To achieve the best possible participation rate, we used Web-based surveys, provided clear instructions, and indicated the expected time required to complete surveys. We used email reminders to improve participation in the second survey.

Initial stakeholder engagement began with orientation to the topic, goals, process, and expectations (Figure 1, bullet 2). We scheduled two 1-hour long conference calls and distributed a brief project overview, a link to the CER, and a list of research gaps identified from the CER via email. Each conference call was followed by electronic correspondence including the revised list of gaps and a second invitation for stakeholders to edit or add questions as necessary. To enhance public engagement, the draft report will be made available for public input for four weeks and stakeholders will be invited to provide comments on the final report.

### Criteria for Prioritization

#### Round One Prioritization

We presented the expanded list of questions to stakeholders via a Web-based survey (Appendix F) that asked stakeholders to rank the importance of each question using a 5-point Likert scale. We a priori considered those questions receiving at least 4.3 points to comprise the highest-rated research needs for further prioritization.

#### Round Two Prioritization

We sent a second Web-based survey (Appendix G) to stakeholders asking them to rank the selected research needs using a prespecified criteria, modified from the Effective Health Care program selection criteria (Table 2) and described in AHRQ Effective Health Care methodologic guidance.35 Stakeholders ranked each research need across the six criteria below using a 5-point Likert scale from 1 (low) to 5 (high). We tallied the number of points for each question across all criteria and present the top scoring questions overall in the Results section below. We a priori considered the research needs receiving a score of 4.0 or more as the highest priority. We selected a second grouping with a score of 3.75–3.99 as second-tier research needs.

Table 2 Prespecified criteria for prioritization of top-rated research needs

Potential value criteria (for significant health impact): addressing evidence gap (knowledge, translation, implementation)
Potential for new knowledge (Research would not be redundant: Strength of evidence is not high for specific outcome (confidence in the estimate of effect is moderate or low); Question not sufficiently researched, including completed and in-process research; Utility of available evidence limited by changes in practice, e.g., disease detection or evolution in technology); more evidence needed about values and preferences influencing balance of benefits and harms/risks.
Potential for significant health impact on the current and projected health status of people with respect to burden of the disease and health outcomes: mortality, morbidity, and quality of life.
Potential to reduce important inappropriate (or unexplained) variation in clinical practices known to relate to quality of care. Potential to resolve controversy or dilemmas in what constitutes appropriate health care. Potential to improve decision-making for patient or provider, by decreasing uncertainty.
Potential for significant economic impact related to the use of health service resources. Many healthcare resource use factors may be expressed as cost. Potential to reduce unnecessary or excessive costs; to reduce high costs due to high volume use; to reduce high costs due to high unit cost or aggregate cost. Costs may impact consumers, patients, care-givers, employers, health care systems, or payers.
Potential risk from inaction: Unintended harms from lack of prioritization of proposed research; opportunity cost of inaction; potential to allow assessment of ethical, legal, social issues pertaining to the condition.
Addresses inequities, vulnerable, diverse populations (including issues for patient subgroups); potential to reduce health inequities; potential to allow assessment of ethical, legal, social issues pertaining to the condition.

Study data were collected and managed using REDCap™ (Research Electronic Data Capture), a secure, Web-based application hosted at Vanderbilt University.36

### Research Needs Development and Research Design Considerations

Key research questions for each evidence gap were generated through an online survey instrument and discussions by the stakeholder panel. The project team compiled a final list of research questions taking the feedback of the panel into consideration. The project team evaluated potential study designs to address each of the top-tier research needs. Consistent with AHRQ published guidance,35 we describe key considerations and study design to address an evidence gap within the context of the following criteria:

- Appropriateness and ability of a given design to yield relevant, valid results
- Advantages and disadvantages of given designs relative to the area of research
- Resource use and ethical, legal, and social considerations
- Availability of relevant data
- Alignment with the system of care for CPP

The project team relied on this framework as a guide during discussions of the least biased study design that was likely to be feasible and affordable. Public comments received after the document is posted will be incorporated into the final report.