# Introduction

Systematic reviews are the standard for synthesizing current scientific knowledge on a particular clinical topic. Thorough and appropriately conducted reviews will often conclude with remarks on the research gaps and highlight areas of uncertainty discovered during analysis of the primary literature. Organized presentation of identified gaps may lead to more rapid generation of subsequent research and aptly direct resources to key future research needs.

The systematic comparative effectiveness review (CER) of noncyclic chronic pelvic pain (CPP) therapies for women was published on the Agency for Healthcare Research and Quality (AHRQ) Web site in January 2012.^1^ The publication details the methods used to plan and execute the systematic review of clinically important questions on management of noncyclic CPP. The results include evidence-based conclusions about the comparative effectiveness of various surgical and nonsurgical therapies for noncyclic CPP, as well as harms of nonsurgical therapies for CPP. The report includes a preliminary discussion on potential future research based upon gaps in knowledge uncovered by the systematic review. The purpose of this report is to present recommendations for future research on CPP that builds upon the findings from the recent systematic review and input from stakeholders. We describe a preliminary but reproducible process that relied upon stakeholder engagement and feedback across prespecified criteria to transform identified research gaps into prioritized research needs.

## Background

CPP in women is a commonly occurring and poorly understood condition. Little consensus on the definition of the condition exists—the duration of pelvic pain considered chronic in published studies varies from 3 months to more than 6 months, and the location and pathology of the pain are largely unspecified.2 The American College of Obstetricians and Gynecologists defines chronic pelvic pain as “noncyclical pain of at least 6 months’ duration that appears in locations such as the pelvis, anterior abdominal wall, lower back, or buttocks, and that is serious enough to cause disability or lead to medical care.”3 Mixed CPP refers to the combination of noncyclic CPP and another pelvic pain that is cyclic or associated with intercourse, bowel movement, or urination. Noncyclic CPP excludes chronic pelvic pain that is limited to dysmenorrhea (pain with menstruation), or dyspareunia (pain with intercourse), dyschezia (pain with bowel movement), or dysuria (pain with urination).4, 5 Noncyclic CPP is sometimes described simply as “chronic pelvic pain” in the literature because many subdivide the pain syndromes into dysmenorrhea, dyspareunia, and nonmenstrual CPP.3 CPP as described throughout this report refers to noncyclic or mixed cyclic/noncyclic pelvic pain unless otherwise noted.

The causes of CPP are not well understood and may be associated with gynecologic (e.g., endometriosis) and non-gynecologic (e.g., irritable bowel syndrome) conditions. Diagnosis of an underlying cause is complicated because the pain is rarely associated with a single underlying disorder or contributing factor.6 Frequently diagnosed etiologies include endometriosis, adhesions, irritable bowel syndrome, and interstitial cystitis/painful bladder syndrome;7 however, a definitive diagnosis is often not made.

### Noncyclic CPP Therapies Systematic Review

In 2011, the Vanderbilt Evidence-based Practice Center completed an AHRQ-funded systematic review of therapies for women with noncyclic CPP. The review nomination, submitted by a health plan medical director, noted that little is known about treating women with CPP and that care is highly variable. Hysterectomy is common treatment option for pelvic pain, but little evidence exists to guide treatment decisions.

The review of therapies for women with CPP was published on the AHRQ Effective Health Care Web site in January 2012. The report focused on the following Key Questions related to therapy:

- Key Question 1. Among women who have been diagnosed with noncyclic/mixed cyclic and noncyclic CPP, what is the prevalence of the following comorbidities: dysmenorrhea, major depressive disorder, anxiety disorder, temporomandibular joint pain disorder, fibromyalgia, irritable bowel syndrome, interstitial cystitis/painful bladder syndrome, complex regional pain syndrome, vulvodynia, functional abdominal pain syndrome, low back pain, headache, and sexual dysfunction?
- Key Question 2. Among women with noncyclic/mixed cyclic and noncyclic CPP, what is the effect of surgical interventions on pain status, functional status, satisfaction with care, and quality of life?
- Key Question 3. What is the evidence that surgical outcomes differ if the etiology of noncyclic/mixed cyclic and noncyclic CPP is identified after surgery?
- Key Question 4. Among women with noncyclic/mixed cyclic and noncyclic CPP, what is the effect of nonsurgical interventions on pain status, functional status, satisfaction with care, quality of life, and harms?
- Key Question 5. What is the evidence for choosing one intervention over another to treat persistent or recurrent noncyclic/mixed cyclic and noncyclic CPP after an initial intervention fails to achieve target outcome(s)?

### Key Findings of the Evidence Report

The literature addressing therapies for CPP in women is of largely poor quality and inconclusive. While half of the literature comprised randomized controlled trials (RCTs), only two were good quality8,9 and three were fair.10–12 Studies providing cross-sectional data about the prevalence of comorbidities varied in quality but were largely poor. Nonetheless, some conclusions can be drawn.

Among studies reporting data on the prevalence of comorbidities, prevalence estimates tended to be more clustered in those studies that employed validated diagnostic criteria (e.g., Rome criteria for irritable bowel syndrome), and studies using validated criteria were of higher quality. Studies of nonsurgical approaches addressed hormonal management of endometriosis-related CPP and were not placebo controlled, thus limiting our ability to understand whether hormonal therapies would be beneficial for women with CPP without endometriosis and whether pain relief reported is due simply to the placebo effect. Some studies reported benefits of other nonsurgical approaches, but non-hormonal and non-pharmacologic management remain understudied.

Across the literature, higher quality intervention studies tended to demonstrate a lack of benefit: lysis of adhesions showed no benefit,9 a selective estrogen receptor modulator had a negative effect on pain.8,13 Some studies suggest benefit of some approaches including depot leuprolide for endometriosis-associated CPP.12

Aside from the lack of benefit reported for adhesiolysis,9 little evidence demonstrates the effectiveness of surgical approaches. Studies reported no differences in improvements in pain scores between groups in studies comparing surgical interventions with diagnostic laparoscopy alone or active surgical interventions. Studies comparing hysterectomy and nonsurgical management14,15 reported similar improvements in pain scores between groups and greater patient satisfaction among women undergoing hysterectomy in a sample of women electing hysterectomy.15 Despite numerous surgical techniques used extensively in treating CPP, few studies included more than 50 participants, and few were considered high quality (two good-quality studies, three fair-quality studies, and 16 poor-quality studies). All of the studies with comparison data failed to demonstrate that surgery in general or any specific surgical technique was more efficacious than either nonsurgical intervention or the comparator technique in improving pain status in patients. No surgical technique was superior, and the evidence to conclude that surgical intervention is either effective or ineffective for the treatment of CPP is insufficient.

Indeed, the strength of evidence for effectiveness across interventions ranges from insufficient to low with few studies comparing the same intervention and variable patient populations. The literature lacks placebo-controlled studies, studies of non-hormonal interventions, studies of non-pharmacologic interventions, and studies comparing medical and surgical management. Studies establishing the benefit of surgery as a treatment option for CPP are also lacking.

Despite a prevalence for CPP rivaling that of widely studied conditions such as asthma,16 little research assessing therapies exists. While there are many publications regarding pelvic pain, there are relatively few addressing noncyclic CPP, and of those, we evaluated few as providing high-quality evidence. In sum, the literature overall is muddled by a lack of standardized definitions for CPP and unclear diagnostic evaluation that make it difficult to determine whether studies truly include women with CPP. Similarly, understanding comorbidity prevalence with CPP is difficult as conditions may be considered part of the differential diagnosis or a concomitant condition.

Improved characterization of the targeted condition, intervention, and population in CPP research is necessary to inform treatment choices for this commonly reported entity. A uniform definition of CPP and standardized evaluation of participants are lacking across the literature; study populations vary, and studies may be reporting effects from treating symptoms rather than a diagnosed condition. Thus our understanding of potential treatment effects is diluted.

#### Gaps in Areas of Research

The CER identified significant gaps in the research literature addressing women with CPP. Specifically, the review found that research addressing therapies for CPP is largely composed of trials of active agents or approaches with little placebo-controlled research and little evidence of thorough identification of patient characteristics and potential etiologies for CPP. Notably, the review did not identify any studies providing evidence that surgical outcomes differ if the etiology of CPP is identified after surgery (Key Question 3). No studies providing evidence for choosing one intervention over another to treat persistent or recurrent CPP after an initial failed intervention (Key Question 5) were found. We added indications for these preliminary gaps to the analytic framework from the full report. The analytic framework illustrates the KQs, population, interventions, comparators, outcomes, timeframes, and settings (PICOTS), and identified research gaps below in Figure 1.

Figure 1 Analytic framework illustrating intervention-related evidence gaps

Abbreviations: CAM=complementary and alternative medicine; KQ=Key Question; BSO=bilateral salpingo-oophorectomy

The figure illustrates a conceptual framework for research on the treatment of women with chronic noncyclic or mixed cyclic/noncyclic pelvic pain. These women, without known or unknown comorbidities, enter into treatment choices. Treatment choices include surgical and nonsurgical approaches that lead to short and long-term outcomes (i.e., pain status, functional status, quality of life, patient satisfaction, and/or harms/adverse events). The outcomes may vary by diagnosis for those patients in whom a likely etiology is or is not found via histopathology. Initial research gaps related to the population, diagnosis, comorbidities, treatment, etiology, and outcomes are depicted within shaded rectangular text boxes at various locations within the framework.

The following sections summarize the gaps in the literature and future research needs described in the CER related to standardized definitions and diagnostic criteria, etiology, iatrogenic pain, impact and resource utilization, followed by a description of methodologic issues relevant to noncyclic CPP.

##### Standardized Definitions and Diagnostic Criteria

As noted in this review and previous studies,2 definitions of CPP vary across the literature and may conflate noncyclic and cyclic pain. Employing standardized definitions of CPP is a critical need in future research to establish the condition under study and the effects of specific therapies. The lack of a standardized conception of CPP likely leads to a dilution of treatment effects that may be present, and clarifying our understanding of patient populations can help to bring treatment outcomes into focus. Similarly, few studies reporting comorbidity data used validated tools to diagnose comorbidities, and many relied on patient self-report. Future research needs related to defining and diagnosing CPP and comorbid conditions include:

- Widespread use of accepted definitions of CPP across studies
- Standard use of validated tools in studies to inform our understanding of the true prevalence of conditions reported to co-occur with CPP
- Larger, prospective studies examining the extent to which comorbidities modify treatment approaches and outcomes in CPP

##### Diagnostic Approaches

Standardized, thorough diagnostic approaches are an important area for future study as the literature lacks clear delineation of patient populations. Moreover, standardized evaluations can be help to ensure that clinicians are treating the actual cause(s) of CPP versus pain symptoms. The International Pelvic Pain Society has published a clinical assessment document that could be utilized to standardize the initial evaluation of potential participants.17 Research needs in this area include:

- Estimation of the accuracy of individual and combinations of diagnostic tests for CPP
- Role of magnetic resonance imaging and positron emission tomography scan in narrowing the differential diagnosis of CPP
- Development and validation of pain assessment tools to capture the multidimensional experience of pelvic pain

##### Etiology

The causes of CPP are not well understood and may be associated with gynecologic (e.g. endometriosis) and non-gynecologic (e.g., irritable bowel syndrome) conditions. Diagnosis of an underlying cause is complicated because the pain is rarely associated with a single underlying disorder or contributing factor. Based on the findings of the CER, future research needs related to etiology of CPP include:

- Analyses of distribution of the underlying causes of CPP
- Identification of subgroups at risk of developing CPP
- Investigations of pelvic floor myofascial dysfunction in CPP
- Effects of sex steroid hormone levels on pain perception

##### Iatrogenic Pain

Iatrogenic pain (pain resulting from a procedure or complication of a procedure performed by a clinician) is another understudied etiologic factor for CPP. Emerging causes of iatrogenic pain include use of permanent mesh (post-mesh pain syndrome), tubal ligation/occlusion (post-tubal syndrome), and endometrial ablation (post-ablative pain syndrome). The CER identified the following future research needs related to iatrogenic causes of CPP:

- Benefits and harms of interventions to treat pelvic organ prolapse and uterine bleeding
- Assessment of chronic postoperative incisional pain as a factor contributing to CPP
- Role of repeat surgeries in the same location as a source of pain
- Identification of the etiology of pain prior to hysterectomy

##### Standardized Outcome Measures

Studies included in the CER used numerous outcomes measures to assess pain, quality of life, and patient satisfaction. While typically used as a measure for pain, visual analog scales varied, making comparisons across studies difficult. Similarly, quality of life measures varied and patient satisfaction was typically reported using instruments not yet validated. The CER concluded that future research on CPP should include the standardized outcome measures such as those recommended by the IMMPACT (Initiative on Methods, Measurement, and Pain Assessment in Clinical Trials) consensus conference.18

##### Nonsurgical and Nonpharmacologic Management

Studies meeting criteria for inclusion in the CER largely assessed surgical and pharmacologic management of CPP, despite research suggesting the need to consider psychological and sociodemographic factors in understanding and treating chronic pain.19–23 Studies of nonsurgical or non-pharmacologic approaches were generally of poor quality but reported some benefit from a pelvic physiotherapy technique,24 ultrasonography plus counseling,25 and an integrated treatment approach.26

The CER authors noted that a better understanding of allied health, integrative medicine, and behavioral approaches (e.g., acupuncture, transcutaneous electrical nerve stimulation, physiotherapy, cognitive behavioral therapy) to CPP is needed. Future research on nonsurgical and non-pharmacologic management of CPP should also include:

- Studies on advice and communication about pain, and education
- Studies of health care settings and consultation styles and their impact on CPP treatments
- High-quality assessments of multidimensional treatment

##### Pharmacologic Approaches

Much of the literature addressing pharmacologic interventions for CPP investigated hormonal therapies in women with endometriosis-associated CPP. Few studies included in the CER were placebo-controlled. The CER recommended that future research on pharmacologic therapy for CPP include placebo-controlled study designs and evaluate nonhormonal agents such as tanezumab.

##### Surgical Compared With Nonsurgical Approaches

The CER found that the current literature also lacks studies comparing surgical and nonsurgical approaches. Two poor-quality cohort studies comparing surgical and nonsurgical approaches reported similar effects on pain status between modalities14, 15 and greater patient satisfaction with hysterectomy compared with nonsurgical management in one study.15 High-quality comparative studies addressing common surgical and medical treatment approaches for CPP are needed.

##### Benefits of Surgical Treatment

The CER revealed that another important area for research lies in establishing whether surgical approaches are of benefit for CPP treatment, and if so, which approaches are superior. One study comparing laparoscopic uterine nerve ablation with diagnostic laparoscopy alone (sham laparoscopic uterine nerve ablation) reported similar outcomes between approaches.10, 27 One study reported no benefit of lysis of adhesions compared with laparoscopy alone,9 and one comparing active approaches (laparoscopic uterine nerve ablation vs. utero-sacral ligament resection)28 reported no differences in pain outcomes between groups. Future research should include large, well conducted studies to help determine surgical outcomes, patients likely to benefit from surgery, and optimal timing of intervention as well as research to classify the therapeutic benefit of diagnostic laparoscopy which is often used as a standard control arm in surgical studies.

##### Impact and Resource Utilization

CPP accounts for an estimated 1 in 10 outpatient gynecology visits, and an estimated $1.2 billion per year is spent on outpatient management of CPP in the United States (adjusted for inflation from $880 million in 1996).29 To understand better how to manage CPP care, future research should seek to understand the impact of CPP on the use of health services and conduct economic analyses to determine the most cost-effective diagnosis and management strategies.

##### Methodologic Issues

In addition to identifying condition-specific gaps in the available evidence, the systematic review of the primary literature on therapy for CPP revealed methodologic limitations of the literature and other important considerations for future study designs.

The evidence report found that few of the 17 RCTs included in the review adhered to standard study design and reporting conventions. In particular, few trials adequately concealed treatment assignments from participants, investigators, and outcome assessors, and just under half of the RCTs (7/17) reported an intention-to-treat-analysis. The drop-out rate exceeded 10 percent in eight studies and more than 20 percent of participants were lost to followup in six out of 17 trials. Most trials (12/17) did report an a priori primary outcome of interest and sample size calculation. Ten adequately reported missing or incomplete outcome data. Among the three included cohort studies, none employed blinded outcome assessors, and one provided an a priori sample size calculation. The dropout rate exceeded 10 percent for all three studies.

The CER found that definitions of CPP and outcome measures varied across studies and few studies provided long-term followup data. Future studies should extend the followup period to assess the degree to which outcomes are durable, especially as many women with CPP fail to achieve adequate pain relief despite multiple interventions. RCTs in this literature also typically included fewer than 150 women with CPP, despite the high reported prevalence of CPP. Future research including larger sample sizes should yield greater confidence in treatment effects.

A thorough diagnostic investigation is necessary to effectively treat any chronic pain. For many conditions, this investigation typically follows a predetermined algorithm, but no such algorithm exists for CPP. The CER recommended that future studies outline and report the diagnostic process for participants. Pelvic pain researchers would improve the overall quality of literature if an established diagnostic algorithm was developed and put forward for use. A standardized assessment of potential study participants and standardized inclusion criteria would permit systematic analysis of data from multiple trials.

Only three trials included in the CER were placebo controlled; the bulk of nonsurgical studies compared active agents, and no surgical studies used a placebo. A major source of both false positive and false negative results in trials of treatment for pain is the placebo effect, which in analgesic trials is often substantial and may have a duration of weeks or months.30

Placebo-controlled trials of any surgical interventions are exceedingly rare. A challenge in interpreting observation trials of surgery, or randomized trials of surgical versus nonsurgical therapy, is that patients could not reasonably be blinded to the intervention,31 which may be responsible for some overestimation of surgical benefits for pain relief.32 Based upon the very small number of placebo-controlled randomized trials, the magnitude of the placebo effect of surgery for pain is about 35 percent.33 As recommended in the CER, future research of interventions for relief of CPP should be placebo-controlled with the exception of small pilot studies to evaluate the potential of a new intervention.

## Scope and Objective

The small and methodologically flawed evidence base discussed in the CER is inadequate to inform treatment decisions for this commonly reported entity. We employed a systematic process to build on research needs identified in the CER and incorporate multiple stakeholder viewpoints. Our objective was to develop a categorization of future research needs related to surgical and nonsurgical interventions for women with CPP with sufficient detail for researchers and individuals or organizations financing a part or all of a project’s cost to use for developing into research proposals or solicitations, respectively. We describe a sequential process for prioritizing research gaps into future research needs (Figure 2). This process begins with identification of evidence gaps from the original systematic review, followed by prioritization of these evidence gaps by stakeholders using prioritization criteria. The top tier of prioritized evidence gaps is research needs. Research questions are developed from these research needs. This process yielded a set of prioritized research needs/research questions and potential study designs to address questions.

Figure 2 Flowchart of future research needs process

Notes: * May include identification of additional evidence gaps. † Reduction through topic consolidation, preliminary prioritization, and consideration of ongoing research (duplication criteria). ‡ Evidence gaps that address specific methods issues would not use PICOTS framework. ¥ May require iterative steps

The figure illustrates the flow of steps in developing the future research needs report. Steps include: 1) Systematic review is published with EPC determined evidence gaps; 2) Orientation of stakeholders to CER question, future research need process, and prioritization criteria; 3) Elaboration and consolidation of evidence gaps through iterative process with stakeholders; 4) Transformation of evidence gaps into research questions using revlevant framework; 5) Ranking of research questions by stakeholders (potential value criteria) resulting in research needs; 6) Addition of study design consideration and feasibility issues; 7) Publication of future research needs document.