# Executive Summary

## Background

In a recently published comparative effectiveness review (CER) of therapies for noncyclic chronic pelvic pain (CPP), several research gaps within the CPP evidence base were identified. The purpose of this report is to present recommendations for future research on CPP based on the findings from that review and input from stakeholders. We describe a preliminary but reproducible process that relied upon stakeholder engagement and feedback across prespecified criteria to transform identified research gaps into prioritized research needs.

CPP in women is a commonly occurring and poorly understood condition. Little consensus on the definition of the condition exists—the duration of pelvic pain considered chronic in published studies varies from 3 to more than 6 months, and the location and pathology of the pain are largely unspecified.1 The American College of Obstetricians and Gynecologists defines chronic pelvic pain as “noncyclical pain of at least 6 months’ duration that appears in locations such as the pelvis, anterior abdominal wall, lower back, or buttocks, and that is serious enough to cause disability or lead to medical care.”2 Noncyclic CPP excludes chronic pelvic pain that is limited to dysmenorrhea (pain with menstruation), or dyspareunia (pain with intercourse), dyschezia (pain with bowel movement), or dysuria (pain with urination).3,4 Mixed CPP refers to the combination of noncyclic CPP and another pelvic pain that is cyclic or associated with intercourse, bowel movement, or urination. CPP as described throughout this report refers to noncyclic or mixed cyclic/noncyclic pelvic pain unless otherwise noted.

Little is known about treating women with CPP and that care is highly variable. Hysterectomy is common treatment option for pelvic pain, but little evidence exists to guide treatment decisions. In 2011, the Vanderbilt Evidence-based Practice Center completed an Agency for Healthcare Research and Quality (AHRQ)-funded systematic review of therapies for women with noncyclic CPP.

Despite a prevalence for CPP rivaling that of widely studied conditions such as asthma,5 little research assessing therapies exists. While there are many publications regarding pelvic pain, there are relatively few addressing noncyclic CPP, and of those, few provide high-quality evidence creating significant gaps in the research literature for treatment of women with noncyclic CPP.

## Methods

Table A outlines the project’s methods, which were modified from those used in prior future research needs projects.6 Briefly, we used a multistep process to identify evidence gaps, beginning with a distillation of the research gaps as reported in the CER. We organized individual research needs using the following categories: standardized definitions and diagnostic criteria, etiology, iatrogenic pain, impact and resource utilization, and methodologic issues. We presented these along with a summary of relevant ongoing research to individuals who agreed to participate in the project as stakeholders.

Table A Summary of steps for developing future research needs

| Approach to Evidence Gap Identification
1. | Generate preliminary list of research gaps based on findings of the CER.
2. | Form stakeholder workgroup with representatives from advocacy organizations, provider community, research community, and funding agencies.
3. | Locate ongoing trials and other funded research.
4. | Conduct conference call with stakeholders to refine initial list of evidence gaps.
| Approach to Prioritization and Stakeholder Engagement for Prioritization
5. | Invite stakeholders to rate perceived importance of individual research gaps.
6. | Cull list of research needs based on stakeholder voting.
7. | Invite stakeholders to prioritize research needs using modified EHC selection criteria.
| Approach to Research Question Development and Considerations for Potential Research Designs
8. | Determine potential study designs to address final list of research needs.
9. | Obtain stakeholder input on the draft research needs report.
10. | Finalize research needs report.

Abbreviations: CER=comparative effectiveness review; EHC=Effective Health Care Program

We sought representation from known experts and others active in the field of noncyclic CPP to provide input on the list of research needs and add additional questions as necessary. Stakeholders were identified from initial lists developed for potential Key Informants and Technical Expert Panel members for the CPP CER. This list was augmented by referrals from the investigative team to form a group broadly representative of research, clinical care, patients, and funders. Potential stakeholders were invited to participate by email. We obtained conflict of disclosures from each participant for review by the Task Order Officer prior to the first scheduled conference call.

We engaged stakeholders agreeing to participate in the project via an initial conference call to introduce the project and to add to the list of gaps identified from the report. This call was followed by an email message including the revised list of gaps and inviting stakeholders to edit or add questions as necessary.

We presented the expanded list of questions to stakeholders via a Web-based survey that asked stakeholders to rate each item using a 5-point Likert scale. We asked stakeholders to consider the overall importance of the question for noncyclic CPP research but did not proscribe specific criteria for prioritizing in the initial survey. We extracted the highest rated items for an additional ranking activity using prespecified criteria.

Using a second Web-based survey, we asked stakeholders to prioritize research needs across six prespecified criteria modified from the Effective Health Care program selection criteria7:

- Potential for new knowledge
- Potential for significant health impact
- Potential to reduce variation in clinical practices
- Potential for significant economic impact
- Potential risk from inaction.
- Potential to address inequities

Stakeholders ranked each question on each of the criteria using a 1 (low) to 5 (high) point scale. We tallied scores across each criterion to determine an overall score for each question and divided questions into top, middle, and lower tiers for both treatment- and methods-focused needs according to overall scores. We provided considerations for each of the top-tier treatment-related needs and proposed a potential research design.

## Results

### Stakeholders

Stakeholders broadly represented clinical, research, and advocacy perspectives in CPP. The panel comprised a total of eleven stakeholders including clinical researchers with expertise in CPP, physical therapists, and a patient advocate.

### Needs Identified in CER

From the CER, the project team organized a list of research gaps to present to the stakeholder group. These needs were initially organized by topic-based and methods-based research gaps. The project team further characterized the research needs into clinical and research related categories (Appendix C of the main report) which was distributed to the stakeholders along with a summary table of ongoing research (Appendix B of the main report).

### Needs Identified From Stakeholder Input

Of 12 individuals who agreed to participate, 11 participated in one of two conference calls. Stakeholders were asked to comment on the list of research gaps from the CER and discuss research issues pertinent to the topic. The moderator (SR) encouraged call participants to propose research needs related to noncyclic CPP that were not captured by the CER-generated list. From these calls, we generated an expanded list of research needs that included 63 items, with 28 derived from the stakeholders and 35 derived from the CER (Appendix E of the main report).

#### Round One Prioritization

We presented the expanded list of research needs to stakeholders in an initial survey. (Appendix F of the main report) We asked stakeholders to rate the research needs according to perceived degree of importance using a 5-point Likert scale. Six of the 12 stakeholders completed the survey. The highest rated research needs (i.e., items scoring at least 4.3 points) needs) were identified from the initial rating survey results.

#### Round Two Prioritization

In the second survey we organized the highest rated research needs identified in the initial survey broadly by area of focus and presented them by category in no particular order. (Appendix G of the main report). We asked stakeholders to rank each of the 31 research needs across the following prespecified selection criteria7 using a 1 (low) to 5 (high) point scale:

- Potential for new knowledge
- Potential for significant health impact
- Potential to reduce inappropriate variation in clinical practices
- Potential for significant economic impact
- Potential risk from inaction
- Potential to address inequities

Seven stakeholders completed the survey. Results were analyzed based on the responses received. We tallied the scores for each question on each criterion to determine an overall score. We considered those questions with an overall score of at least 4.0 (n=6) to comprise the top-tier of research needs (Table B).

Table B Top-tier research needs^a^

Score | Research Need
4.31 | Determine which patients are likely to benefit from surgery.
4.22 | Develop standardized diagnostic criteria.
4.16 | Identify risk associations and women at risk for developing noncyclic chronic pelvic pain.
4.15 | Determine the overall role of surgery.
4.04 | Conduct studies on the management of patients who have failed pharmacologic treatment.
4.03 | Identify the most cost effective diagnostic and management strategies.

Notes:

a Research needs with an average score of 4.0 or higher from second survey

Items with an overall score of 3.75–3.99 (n=9) comprise the second-tier of research needs (Table C). Of note, the scores were all very close, and no set of recommended studies should be considered low priority. The rating provides a relative measure; all of the research questions are important, but a subset comprises a priority set that should be addressed first.

Table C Second-tier research needs^a^

Score | Research Need
3.98 | Conduct studies on cognitive behavior therapy.
3.94 | Standardize diagnostic evaluations including history and physical.
3.90 | Standardize optimal surgical outcomes including followup interval (e.g., long-term outcomes).
3.86 | Determine the accuracies of individual and combined diagnostic tests.
3.84 | Conduct studies on patient education.
3.82 | Determine patient dissatisfaction with care.
3.80 | Document the treatment effect of diagnostic laparoscopy.
3.80 | Conduct studies on provider education.
3.78 | Assess the impact of noncyclic chronic pelvic pain on the use of health services.

Notes:

a Research needs with an average score between 3.75–3.99 from second survey

#### Research Design Considerations

The investigative team independently developed suggestions and considerations for potential study designs relevant to each of the top-tier research needs (Table D). The top-tier research needs underscore the lack of findings reported in the initial CER while others, such as diagnosis or cost effectiveness, are more general and indirectly related to the CER, although still partially within the scope of the CER.

Table D Top-tier research needs: PICOTS, study designs, considerations, and relationship to CER

Research Need Source | PICOTS Element(s) | Potential Study Designs and Considerations | Relationship to CER
Determine which patients are likely to benefit from surgery. CER | P: Women with noncyclic CPP I: Surgical C: Surgical or nonsurgical O: Symptom resolution; QOL T: >12 months S: Community and clinic | Diagnostic and treatment RCT with subpopulation analysis and/or strict inclusion criteria of a well-defined population; - Comparison of treatment may be surgery A vs. surgery B or surgery vs. nonsurgical intervention or surgery vs. sham-surgery.; - Standardizing surgical interventions can be problematic. Surgical care is a highly technical, complex process and requires the coordination of many individuals and systems. | Addressed specifically by KQ2 and KQ3 of the CER. Of seven studies addressing KQ2, one was assessed as good, one as fair, and five as poor quality. No studies addressing KQ3 were identified.
Develop standardized diagnostic criteria. CER | P: Women with pelvic pain I: Diagnostic test/criteria C:Diagnostic test/criteria O: Diagnostic accuracy T: N/A S: Clinic | Validation study of consensus-developed diagnostic criteria, in the light of systematic reviews (international, multisite, between-subjects design); - Requires an international effort. (Comparison process: Rome I, II, III criteria for diagnostic criteria for IBS and validation, diagnostic criteria for headache, complex regional pain syndrome, and psychiatric disorders).; - Challenge precluding a RCT is that there is no gold standard diagnostic test. | Addressed indirectly by all KQs of the CER. Across all studies for therapeutic interventions there were large inconsistencies noted in the CER for diagnostic criteria. May benefit from a systematic review to assess status of existing, if any, diagnostic criteria for CPP.
Identify risk associations and women at risk for developing noncyclic chronic pelvic pain. CER | P: Women with and without noncyclic CPP I: N/A C: N/A O: Noncyclic CPP diagnosis and diagnosis of an at-risk comorbid condition T: >12 months S: Community and clinic | Observational study: prospective cohort (longitudinal) or case-control study; - Cohort study would need to be large and long term. Expensive because development of CPP ‘rare’: a solution would be to add to a larger prefunded cohort study.; - Case-control studies can be very efficient; but only one outcome per study; threats to validity include recall bias, control selection, and response rates.; - Other challenges include the difficulty imposed by confounding (mixing of effects) and risk factor interaction (synergy, antagonism). | Addressed partially by KQ1 of the CER. Additional systematic review may be needed to identify studies not included within the scope of CER.
Determine the overall role of surgery. Stakeholders | P: Women with noncyclic CPP I: Surgical C: Surgical or nonsurgical O: Symptom resolution; QOL T: >12 months S: Community and clinic | Prospective cohort; - Common critiques are that observational research studies systematically overestimate treatment effect and are limited by unavoidable confounding and bias. To account for these potential limitations, investigators can use several statistical and methodological techniques, including regression, stratification, and patient matching.; - Standardizing surgical interventions can be problematic. Surgical care is a highly technical, complex process and requires the coordination of many individuals and systems. | Addressed specifically by KQ2 of the CER. Of seven studies addressing KQ2, one was assessed as good, one as fair, and five as poor quality.
Conduct studies on the management of patients who have failed pharmacologic treatment. CER | P: Women with noncyclic CPP that have failed prior treatment I: Surgical or nonsurgical C: Surgical, nonsurgical, no treatment O: Symptom resolution; QOL T: >6 months S: Clinic | RCT (optimal design for therapy should be placebo-controlled, double-blind, parallel group, and randomized to treatment allocation); - Well-defined inclusion and exclusion criteria will be necessary, to define “failure” for every pharmacologic treatment.; - Challenges include high placebo response rate, fluctuating symptoms, heterogeneous and complex mechanisms, avoiding bias, contamination by over-the-counter treatments or drugs for other conditions, avoiding harm, duration of the treatment intervention, frequency of treatment, and difficulty blinding the intervention | Addressed specifically by KQ5 of the CER; however, no studies addressing KQ5 were identified in the CER.
Identify the most cost effective diagnostic and management strategies. CER | P: Women with noncyclic CPP I: Diagnostic test, surgical or nonsurgical therapy C: Diagnostic test, surgical or nonsurgical therapy O: Resource utilization outcomes T: >12 months S: Clinic | Decision analytic modeling comparison of two or more alternatives or designed within a clinical trial (RCT: running in parallel with the main study is a prospective economic analysis); - Not appropriate for placebo-controlled or sham-surgery as comparator, because the placebo arm limits generalizability to clinical practice. | Not addressed by KQs of the CER. Consider systematic reviews to identify studies focused on diagnosis of CPP.

Abbreviations: CER=comparative effectiveness review; CPP=chronic pelvic pain; IBS=irritable bowel syndrome; KQ=Key Question; N/A=not applicable; PICOTS=population, intervention, comparator, outcome, timing, setting; QOL=quality of life; RCT=randomized controlled trial.

## Discussion

The findings of this future research need project suggest that the current status of scientific knowledge regarding treatment for noncyclic CPP is limited in both overall quality and quantity. During discussions with the stakeholders, concerns for lack of standardized definitions, diagnosis and outcome measures recurrently eclipsed specific objectives for specific treatment options as these deficiencies markedly limit the scientific field as a whole. Stakeholders prioritized future research needs identifying general uncertainties about CPP over more specifically defined topics, including specific treatment modalities and therapies. None of the identified needs were completely beyond the scope of the CER, however, some were only partially addressed in that project and additional systematic reviews may be warranted to fully assess the status of published studies concerning those specific needs and research gaps, as indicated in Table D.

One of the strengths of our process included the constituents of the stakeholder participants. CPP is a multifactorial condition treated and managed by a variety of provider types and specialties. Reflective of this variety in providers, we were able to recruit a diverse group of stakeholders for this project. We utilized an internet-based data management system, REDCap™ (Research Electronic Data Capture), to solicit Web-based survey responses from the stakeholders. REDCap allows for variable output formats, facilitating data analysis and synthesis. Our hope was that this would increase efficiency in soliciting stakeholder responses, allowing them to complete the surveys at times and locations convenient to them. REDCap also facilitated data consolidation and review of survey results.

Participation was acceptable during all phases of the project. Stakeholder participation exceeded 50 percent, although it did not reach 100 percent for any step; it is unknown whether other methods could have improved participation. Additional work is needed to further validate the use of this tool in this future research need process.

Methodology for conducting future research need projects is evolving; presently, there are few prescribed methods for research needs prioritization. We elected to follow the paradigm suggested in a draft AHRQ methods report, with some modifications dictated by the nature of the condition under study.

Presently, the state of clinical research for treatments of noncyclic CPP is incomplete and limited by knowledge gaps in fundamental understanding and characterization of the condition. The future research needs identified and prioritized by a diverse group of stakeholders through the process described in this report acknowledge these gaps and suggest that future research in CPP is needed and should be prioritized to address many of these fundamental concerns.

During these discussions with the stakeholders, concerns for lack of standardized definitions, diagnosis and outcome measures recurrently eclipsed specific objectives for specific treatment options as these deficiencies markedly limit the scientific field as a whole.

## Conclusion

The authors of this report built upon the findings from a previous systematic review of therapies for noncyclic CPP to identify a comprehensive list of research gaps for ranking and prioritization. Specific research gaps reflected extensive needs for future research in the areas of diagnosis, standardization, etiology and treatment. Needs were predominately general in nature, reflecting a broad scope of uncertainties within the current state of the science. Specific deficiencies addressed the need for standardized approaches to diagnosis and outcome assessment, and methods to improve management of a poorly characterized condition.

Our multistep process for identifying, expanding, and prioritizing research needs to advance research in the area of noncyclic CPP resulted in a list of research topics to fill specific knowledge gaps. The highest priority research questions were general, reflecting the recognition of broad gaps in the evidence. These research needs include diagnostic criteria validation, identification of subpopulations, comorbid conditions and risk factors, and the role of surgery as a therapeutic intervention. All research studies would be enhanced by multiple site involvement. Although strict inclusion criteria would confer a group of subjects with a similar condition, the more strict the inclusion criteria, the less applicable the results will be for real-world clinical practice. For therapeutic interventions, the recognition of a significant placebo effect in chronic pain informs the recommendation for randomized controlled trials. For therapeutic intervention studies, study design should include a commitment to a choice of superiority, equivalence, or noninferiority design, and a sample size calculation that accounts for the range of possible effect size, placebo effect, and chance.

## References

1 Williams RE, Hartmann KE, Steege JF. Documenting the current definitions of chronic pelvic pain: implications for research. Obstet Gynecol. Apr. 2004;103(4:):686-91. [pmid: 15051560].
2 ACOG Practice Bulletin No. 51. Chronic pelvic pain. Obstet Gynecol. Mar. 2004;103(3:):589-605. [pmid: 14990428].
3 Stones W, Cheong Ying C, Howard Fred M, et al. Interventions for treating chronic pelvic pain in women, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2005.
4 Leserman J, Zolnoun D, Meltzer-Brody S, et al. Identification of diagnostic subtypes of chronic pelvic pain and how subtypes differ in health status and trauma history. Am J Obstet Gynecol. Aug. 2006;195(2:):554-60. discussion 60–1. [pmid: 16769027].
5 Zondervan KT, Yudkin PL, Vessey MP, et al. Prevalence and incidence of chronic pelvic pain in primary care: evidence from a national general practice database. Br J Obstet Gynaecol. Nov. 1999;106(11:):1149-55. [pmid: 10549959].
6 Agency for Healthcare Research and Quality. Future Research Needs - Methods Research Series. 2010. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=521. Accessed July 6, 2012.
7 Agency for Healthcare Research and Quality. Prioritization Criteria Methodology for Future Research Needs Proposals Within the Effective Health Care Program. 2010. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=964&pageaction=displayproduct. Accessed July 6, 2012.