# Acknowledgments

We are indebted to the stakeholders who committed time, expertise and thoughtful insight to this project. We appreciate the support of the AHRQ Task Officer, Shilpa Amin, M.D., M.BSc., FAAFP, and we gratefully acknowledge the extraordinary work of the team of investigators who authored Noncyclic Chronic Pelvic Pain Therapies for Women: Comparative Effectiveness.