# Discussion

For this project, we used a three-step iterative process for identifying and prioritizing evidence gaps and research questions related to therapies for women with noncyclic chronic pelvic pain (CPP), incorporating input from a stakeholder panel. Initially, we included evidence gaps identified and future research needs proposed by the original comparative effectiveness review (CER) and solicited additional suggestions from the stakeholders during the first step of this process. We modified the wording of some future research needs for clarity and combined similar future research needs when redundant. This resulted in a list of 63 future research needs.

During the second step, stakeholders provided initial prioritizations on the inclusive list of future research needs, based on responses to a Web-based survey, narrowing the list to 31 items. In the final step, stakeholders prioritized the top-tier of future research needs using prespecified criteria to develop the final list of top-priority future research needs. The final six top-tier future research needs identified from the stakeholder engagement process, reflect the breadth of Key Questions from the original CER, which covered prevalence of comorbidities (Key Question 1), surgical treatments (Key Question 2), the role of etiology identified after surgery on surgical outcomes (Key Question 3), nonsurgical treatments (Key Question 4) and treatment options for failed interventions (Key Question 5).

As noted in the original CER, the findings of this future research need project suggest that the current status of scientific knowledge regarding treatment for noncyclic CPP is limited in both overall quality and quantity of impactful research. It may not be unexpected, therefore, that the research gaps and future research needs are broad in scope and generalized with regards to terminology. It also may not be unexpected that most of the highest priority needs overlap with the research gaps identified in the original CER. Many of our stakeholders remarked on how poorly understood CPP is in terms of disease characterization, definition, and etiology. Furthermore, they acknowledged that definitions of outcomes inherent to studies concerning therapies were not standardized and thus often not comparable. During these discussions with the stakeholders, concerns for lack of standardized definitions, diagnosis and outcome measures recurrently eclipsed specific objectives for specific treatment options as these deficiencies markedly limit the scientific field as a whole. Perhaps reflective of these concerns, in the final steps of this process stakeholders prioritized future research needs identifying general uncertainties about CPP over more specifically defined topics, including specific treatment modalities and therapies.

We did not specifically evaluate the future needs prioritizations in either step according to stakeholder characteristics and did not solicit information regarding stakeholders’ preferences for ranking certain topics. We felt the limited number of stakeholders precluded meaningful categorization of members and thus any insight from analyzing the results according to stakeholder characteristics would be of questionable benefit. Furthermore, it may jeopardize the anonymity of the prioritization process. The anonymous and individualized aspect of our prioritizing methods allows equal representation from all stakeholders, regardless of background or experience with the clinical condition.

None of the six top future research needs is currently being addressed by ongoing clinical studies, based on the results of our search. Some of the ongoing trials at least partly address future research needs delegated to the lower tiers of prioritization. While we felt that none of the identified needs were completely beyond the scope of the CER, some were only partially addressed in that project and additional systematic reviews may be warranted to fully assess the status of published studies concerning those specific needs and research gaps, as indicated in Table 6. One of the strengths of our process included the constituents of the stakeholder participants. CPP is a multifactorial condition treated and managed by a variety of provider types and specialties, including allied health professionals and others. Reflective of this variety in provider types, we were able to recruit a diverse group of providers as stakeholders for this future research need project, which strengthens the face validity of the results of the research prioritization. In addition, our investigator team was comprised of two members from the original CER, including the Principal Investigator (JA). This afforded familiarity and expertise with the topic and current status of existing research within the field.

No stakeholders disclosed financial or other conflicts of interest that could bias the findings related to the future research need project. Participation was acceptable during all phases of the project. All stakeholders were present on the initial telephone conference call, albeit individual participation in that discussion was varied and immeasurable, which is a recognized difficulty in this process.35 Participation in the prioritization process was moderate, with 55 and 64 percent of stakeholders responding to the first and second surveys, respectively. We did not solicit feedback from the stakeholders regarding their experience with participation in this project, so we are unable to comment on why participation varied during each step of the process. Stakeholder engagement and retention may vary because of the nature of clinical condition or topic or because of logistical or technical aspects of planning and engagement. As we were concerned with limiting the scheduling and effort burdens that may be imposed on the stakeholders, during planning for this project, we tried to incorporate methods (e.g. Web-based survey and email correspondence) that would facilitate convenience, although we did not systematically evaluate whether this affected participation rates.

In this project, we utilized an emerging technological feature to solicit Web-based survey responses from the stakeholders. REDCap™ (Research Electronic Data Capture) is an internet-based data management system that allows direct data population and storage for survey responses. It also allows for variable output formats, facilitating data analysis and synthesis. Our hope was that this would result in increased efficiency in soliciting stakeholder responses, allowing them to complete the surveys at times and locations convenient to them. This was of particular interest as our stakeholder group contained European members, which added to potential scheduling conflicts for teleconferencing. The use of REDCap also facilitated data consolidation and review after the surveys were completed. This approach resulted in stakeholder participation rates of over half of the team members; it is unknown whether other methods could have improved this participation rate. Additional work is needed to further validate the use of this tool in this future research need process.

Methodology for conducting future research need projects is evolving; presently, there are few prescribed methods for research needs prioritization. We elected to follow the paradigm suggested in a draft Agency for Healthcare Research and Quality (AHRQ) report using the Prioritization Criteria Methods (PiCMe), with some modifications dictated by the nature of the condition under study. One component of the PiCMe paradigm is development of specific research questions designed around the “patient, intervention, comparator, outcome, setting” (PICOS) framework and integrating this into the final research needs prioritization. Because relatively nonspecific and broad knowledge gaps were identified by the original CER and stakeholder input, we did not feel such specific details were appropriate as they may be interpreted as being overly proscriptive in nature and may in fact hinder investigator-initiated research.35

Presently, the state of clinical research for treatments of noncyclic CPP is incomplete and limited by knowledge gaps in fundamental understanding and characterization of the clinical condition. Through the process described in this report a diverse group of stakeholders acknowledged known gaps and suggested that ample future research in CPP is needed and that research efforts to address these gaps should be prioritized.