# Conclusion

The authors of this report built upon the findings from a previous systematic review of therapies for noncyclic chronic pelvic pain (CPP) to identify a comprehensive list of research gaps for ranking and prioritization. Specific research gaps reflected extensive needs for future research in the areas of diagnosis, standardization, etiology and treatment. Needs were predominately general in nature, reflecting a broad scope of uncertainties within the current state of the science. Specific deficiencies addressed the need for standardized approaches to diagnosis and outcome assessment, and methods to improve management of a poorly characterized condition.

Our multistep process for identifying, expanding, and prioritizing research needs to advance research in the area of noncyclic CPP resulted in a list of research topics to fill specific knowledge gaps. The highest priority research questions were general, reflecting the recognition of broad gaps in the evidence. These research needs include diagnostic criteria validation, identification of subpopulations, comorbid conditions and risk factors, and the role of surgery as a therapeutic intervention. All research studies would be enhanced by multiple site involvement. Although strict inclusion criteria would confer a group of subjects with a similar condition, the more strict the inclusion criteria, the less applicable the results will be for real-world clinical practice. For therapeutic interventions, the recognition of a significant placebo effect in chronic pain informs the recommendation for randomized controlled trials. For therapeutic intervention studies, study design should include a commitment to a choice of superiority, equivalence, or noninferiority design, and a sample size calculation that accounts for the range of possible effect size, placebo effect, and chance.