# Survey 2 Rank-Ordered Results

Rank | Research Need
1 | Determine which patients are likely to benefit from surgery.
2 | Develop standardized diagnostic criteria.
3 | Identify risk associations and women at risk for developing noncyclic chronic pelvic pain.
4 | Determine the overall role of surgery.
5 | Conduct studies on the management of patients who have failed pharmacologic treatment.
6 | Identify the most cost effective diagnostic and management strategies.
7 | Conduct studies on cognitive behavior therapy.
8 | Standardize diagnostic evaluations including history and physical.
9 | Standardize optimal surgical outcomes including followup interval (e.g., long-term outcomes).
10 | Determine the accuracies of individual and combined diagnostic tests.
11 | Conduct studies on patient education.
12 | Determine patient dissatisfaction with care.
13 | Document the treatment effect of diagnostic laparoscopy.
13 | Conduct studies on provider education.
15 | Assess the impact of noncyclic chronic pelvic pain on the use of health services.
16 | Collect and analyze data to inform health care utilization and cost relationship.
17 | Develop standardized scales to assess quality of life for patients with noncyclic chronic pelvic pain.
18 | Conduct studies on self-management.
18 | Characterize and document the distribution and prevalence of comorbidities and conditions associated with noncyclic chronic pelvic pain.
20 | Determine the optimal timing of surgical intervention.
21 | Conduct studies on physiotherapy.
22 | Determine optimal followup to assess outcomes following surgical interventions.
22 | Determine the direct and indirect costs that contribute to health care expenditures and economic impact.
24 | Determine the role of idiopathic causes in the pathophysiology of noncyclic chronic pelvic pain.
24 | Determine the role of condition-specific causes (e.g., endometriosis, pelvic adhesions, pelvic congestion, etc.) in the pathophysiology of noncyclic chronic pelvic pain.
26 | Determine the role of musculoskeletal evaluations on resource use.
27 | Clinician education on communication of laparoscopy results to patients.
28 | Characterize the role of the patient-provider relationship on surgical outcomes.
29 | Characterize the distribution of symptom components (e.g., dyspareunia, dysmenorrhea, etc.) of noncyclic chronic pelvic pain.
30 | Characterize chronic pelvic pain subtypes, including the significance of differentiation between cyclic and noncyclic.
31 | Determine the role of surgical or pathologic diagnosis on treatment outcomes.

Notes: Top tier: Items ranked 1–6 (research needs with an overall score above 4.0); Second tier: Items ranked 7–15 (research needs with an overall score of 3.75–3.99)