# Survey 2 Results

Domain | ID 1 | ID 2 | ID 3 | ID 4 | ID 5 | ID 6 | ID 7 | Domain Average | Item Average | Rank Order
healthimpact_1 | 4 | 3 | 5 | 5 | 5 | 5 | 5 | 4.57 | 3.84 | 11
reducevariation_1 | 4 | 3 | 4 | 3 | 2 | 5 | 5 | 3.71 | 3.84 | 11
economicimpact_1 | 4 | 2 | 4 | 4 | 4 | 5 | 5 | 4.00 | 3.84 | 11
inaction_1 | 3 | 2 | 4 | 4 | 3 | 4 | 4 | 3.43 | 3.84 | 11
inequities_1 | 3 | 3 | 5 | 4 | 4 | 3 | 4 | 3.71 | 3.84 | 11
elsissues_1 | 3 | 3 | 4 | 5 | 2 | 2 | 4 | 3.29 | 3.84 | 11
newknowledge_1 | 5 | 2 | 4 | 4 | 4 | 5 | 5 | 4.14 | 3.84 | 11
healthimpact_2 | 4 | 3 | 5 | 5 | 4 | 3 | 4 | 4.00 | 3.39 | 27
reducevariation_2 | 4 | 4 | 5 | 5 | 4 | 3 | 5 | 4.29 | 3.39 | 27
economicimpact_2 | 4 | 3 | 4 | 4 | 4 | 1 | 3 | 3.29 | 3.39 | 27
inaction_2 | 4 | 2 | 4 | 5 | 2 | 2 | 4 | 3.29 | 3.39 | 27
inequities_22_b93 | 2 | 2 | 4 | 5 | 2 | 1 | 3 | 2.71 | 3.39 | 27
elsissues_22_6f6 | 3 | 2 | 5 | 5 | 2 | 1 | 4 | 3.14 | 3.39 | 27
newknowledge_22_e80 | 1 | 3 | 5 | 4 | 3 | 2 | 3 | 3.00 | 3.39 | 27
healthimpact_22_40a | 5 | 5 | 5 | 4 | 4 | 5 | 5 | 4.71 | 4.31 | 1
reducevariation_22_ab3 | 5 | 4 | 4 | 4 | 4 | 5 | 5 | 4.43 | 4.31 | 1
economicimpact_22_2e4 | 5 | 5 | 5 | 5 | 5 | 5 | 5 | 5.00 | 4.31 | 1
inaction_22_d5d | 5 | 5 | 4 | 2 | 4 | 4 | 4 | 4.00 | 4.31 | 1
inequities_2 | 5 | 3 | 4 | 4 | 4 | 3 | 5 | 4.00 | 4.31 | 1
elsissues_2 | 5 | 3 | 4 | 4 | 4 | 1 | 4 | 3.57 | 4.31 | 1
newknowledge_2 | 5 | 4 | 5 | 4 | 3 | 5 | 5 | 4.43 | 4.31 | 1
healthimpact_3 | 5 | 4 | 4 | 5 | 5 | 3 | 4 | 4.29 | 3.72 | 17
reducevariation_3 | 5 | 4 | 4 | 3 | 4 | 2 | 5 | 3.86 | 3.72 | 17
economicimpact_3 | 5 | 3 | 3 | 4 | 4 | 2 | 4 | 3.57 | 3.72 | 17
inaction_3 | 3 | 4 | 3 | 4 | 4 | 1 | 4 | 3.29 | 3.72 | 17
inequities_3 | 3 | | 3 | 5 | 4 | 1 | 5 | 3.50 | 3.72 | 17
elsissues_3 | 3 | 4 | 3 | 5 | 4 | 1 | 5 | 3.57 | 3.72 | 17
newknowledge_3 | 2 | 5 | 4 | 5 | 4 | 3 | 5 | 4.00 | 3.72 | 17
healthimpact_4 | 5 | 5 | 4 | 5 | 4 | 5 | 5 | 4.71 | 4.22 | 2
reducevariation_4 | 5 | 5 | 4 | 5 | 4 | 5 | 5 | 4.71 | 4.22 | 2
economicimpact_4 | 5 | 5 | 5 | 4 | 4 | 4 | 5 | 4.57 | 4.22 | 2
inaction_4 | 3 | 4 | 5 | 4 | 4 | 3 | 5 | 4.00 | 4.22 | 2
inequities_4 | 4 | 3 | 5 | 5 | 4 | 1 | 5 | 3.86 | 4.22 | 2
elsissues_4 | 3 | 3 | 4 | 4 | 4 | 1 | 5 | 3.43 | 4.22 | 2
newknowledge_4 | 2 | 5 | 5 | 5 | 4 | 4 | 5 | 4.29 | 4.22 | 2
healthimpact_5 | 4 | 4 | 5 | 4 | 4 | 5 | 5 | 4.43 | 3.94 | 8
reducevariation_5 | 5 | 4 | 5 | 4 | 4 | 5 | 5 | 4.57 | 3.94 | 8
economicimpact_5 | 3 | 4 | 3 | 4 | 4 | 4 | 5 | 3.86 | 3.94 | 8
inaction_5 | 3 | 4 | 4 | 3 | 4 | 3 | 5 | 3.71 | 3.94 | 8
inequities_5 | 2 | 3 | 4 | 4 | 4 | 1 | 5 | 3.29 | 3.94 | 8
elsissues_5 | 3 | 4 | 4 | 4 | 4 | 1 | 5 | 3.57 | 3.94 | 8
newknowledge_5 | 3 | 4 | 5 | 4 | 4 | 4 | 5 | 4.14 | 3.94 | 8
healthimpact_6 | 5 | 4 | 5 | 4 | 3 | 3 | 3 | 3.86 | 3.73 | 16
reducevariation_6 | 4 | 5 | 5 | 3 | 4 | 4 | 3 | 4.00 | 3.73 | 16
economicimpact_6 | 5 | 5 | 5 | 5 | 5 | 4 | 5 | 4.86 | 3.73 | 16
inaction_6 | 3 | 3 | 4 | 3 | 3 | 3 | 4 | 3.29 | 3.73 | 16
inequities_6 | 1 | 3 | 4 | 4 | 4 | 2 | 4 | 3.14 | 3.73 | 16
elsissues_6 | 3 | 3 | 5 | 3 | 3 | 1 | 4 | 3.14 | 3.73 | 16
newknowledge_6 | 2 | 4 | 5 | 4 | 4 | 4 | 4 | 3.86 | 3.73 | 16
healthimpact_7 | 4 | 5 | 5 | 4 | 4 | 3 | 4 | 4.14 | 3.86 | 10
reducevariation_7 | 4 | 5 | 5 | 4 | 4 | 3 | 4 | 4.14 | 3.86 | 10
economicimpact_7 | 4 | 5 | 4 | 4 | 5 | 3 | 5 | 4.29 | 3.86 | 10
inaction_7 | 4 | 5 | 4 | 4 | 4 | 1 | 4 | 3.71 | 3.86 | 10
inequities_7 | 3 | 5 | 4 | 4 | 4 | 1 | 2 | 3.29 | 3.86 | 10
elsissues_7 | 3 | 4 | 4 | 3 | 4 | 1 | 3 | 3.14 | 3.86 | 10
newknowledge_7 | 5 | 5 | 5 | 4 | 4 | 3 | 4 | 4.29 | 3.86 | 10
healthimpact_8 | 3 | 3 | 5 | 4 | 3 | 5 | 3 | 3.71 | 3.78 | 15
reducevariation_8 | 1 | 2 | 5 | 3 | 3 | 5 | 3 | 3.14 | 3.78 | 15
economicimpact_8 | 5 | 3 | 5 | 5 | 5 | 5 | 4 | 4.57 | 3.78 | 15
inaction_8 | 3 | 3 | 4 | 4 | 3 | 3 | 3 | 3.29 | 3.78 | 15
inequities_8 | 5 | 4 | 4 | 4 | 4 | 3 | 4 | 4.00 | 3.78 | 15
elsissues_8 | 5 | 4 | 5 | 3 | 4 | 1 | 4 | 3.71 | 3.78 | 15
new_knowledge_8 | 4 | 3 | 5 | 4 | 3 | 4 | 5 | 4.00 | 3.78 | 15
healthimpact_9 | 5 | 3 | 5 | 2 | 3 | 3 | 5 | 3.71 | 3.42 | 26
reducevariation_9 | 5 | 3 | | 2 | 3 | 3 | 5 | 3.50 | 3.42 | 26
economicimpact_9 | 5 | 3 | 4 | 2 | 3 | 3 | 5 | 3.57 | 3.42 | 26
inaction_9 | 5 | 3 | 4 | 2 | 3 | 1 | 4 | 3.14 | 3.42 | 26
inequities_9 | 5 | 2 | 4 | 3 | 3 | 1 | 5 | 3.29 | 3.42 | 26
elsissues_9 | 5 | 2 | 4 | 3 | 3 | 1 | 4 | 3.14 | 3.42 | 26
newknowledge_9 | 5 | 2 | 5 | 3 | 3 | 2 | 5 | 3.57 | 3.42 | 26
healthimpact_10 | 5 | 4 | 5 | 5 | 5 | 1 | 5 | 4.29 | 3.71 | 18
reducevariation_10 | 5 | 3 | 5 | 3 | 4 | 1 | 3 | 3.43 | 3.71 | 18
economicimpact_10 | 5 | 4 | 4 | 5 | 4 | 1 | 4 | 3.86 | 3.71 | 18
inaction_10 | 4 | 3 | 4 | 4 | 4 | 1 | 3 | 3.29 | 3.71 | 18
inequities_10 | 4 | 3 | 5 | 5 | 4 | 1 | 3 | 3.57 | 3.71 | 18
elsissues_10 | 4 | 3 | 5 | 5 | 4 | 1 | 3 | 3.57 | 3.71 | 18
newknowledge_10 | 4 | 4 | 5 | 5 | 5 | 1 | 4 | 4.00 | 3.71 | 18
healthimpact_11 | 5 | 4 | 5 | 5 | 3 | 5 | 5 | 4.57 | 3.90 | 9
reducevariation_11 | 5 | 4 | 5 | 4 | 3 | 5 | 3 | 4.14 | 3.90 | 9
economicimpact_11 | 5 | 4 | 5 | 4 | 3 | 5 | 3 | 4.14 | 3.90 | 9
inaction_11 | 5 | 3 | 4 | 3 | 3 | 4 | 3 | 3.57 | 3.90 | 9
inequities_11 | 5 | 4 | 5 | 4 | 3 | 1 | 3 | 3.57 | 3.90 | 9
elsissues_11 | 5 | 4 | 5 | 3 | 3 | 1 | 2 | 3.29 | 3.90 | 9
newknowledge_11 | 5 | 4 | 5 | 4 | 2 | 4 | 4 | 4.00 | 3.90 | 9
healthimpact_12 | 5 | 5 | 5 | 5 | 4 | 5 | 5 | 4.86 | 4.15 | 4
reducevariation_12 | 5 | 4 | 4 | 5 | 4 | 5 | 4 | 4.43 | 4.15 | 4
economicimpact_12 | 5 | 4 | 5 | 5 | 5 | 5 | 5 | 4.86 | 4.15 | 4
inaction_12 | 5 | 4 | 5 | | 4 | 5 | 3 | 4.33 | 4.15 | 4
inequities_12 | 5 | 3 | 5 | 4 | 4 | 1 | 2 | 3.43 | 4.15 | 4
elsissues_12 | 5 | 3 | | 4 | 4 | 1 | 2 | 3.17 | 4.15 | 4
newknowledge_12 | 5 | 3 | 4 | 4 | 3 | 5 | 4 | 4.00 | 4.15 | 4
healthimpact_13 | 5 | 4 | 4 | 5 | 3 | 4 | 5 | 4.29 | 3.55 | 22
reducevariation_13 | 5 | 4 | 4 | 5 | 3 | 4 | 4 | 4.14 | 3.55 | 22
economicimpact_13 | 5 | 3 | 4 | 4 | 3 | 4 | 3 | 3.71 | 3.55 | 22
inaction_13 | 4 | 3 | 4 | 4 | 3 | 3 | 4 | 3.57 | 3.55 | 22
inequities_13 | 4 | 2 | 4 | 4 | 3 | 1 | 2 | 2.86 | 3.55 | 22
elsissues_13 | 4 | 2 | 4 | 4 | 3 | 1 | 2 | 2.86 | 3.55 | 22
newknowledge_13 | 3 | 3 | 4 | 4 | 3 | 4 | 3 | 3.43 | 3.55 | 22
healthimpact_14 | 3 | 3 | 5 | 5 | 4 | 4 | 5 | 4.14 | 3.43 | 24
reducevariation_14 | 1 | 3 | 5 | 4 | 4 | 3 | 4 | 3.43 | 3.43 | 24
economicimpact_14 | 3 | 3 | 5 | 5 | 4 | 3 | 3 | 3.71 | 3.43 | 24
inaction_14 | 1 | 3 | 5 | 5 | 3 | 2 | 3 | 3.14 | 3.43 | 24
inequities_14 | 1 | 2 | 5 | 5 | 4 | 1 | 2 | 2.86 | 3.43 | 24
elsiusses_14 | 3 | 2 | 5 | 5 | 4 | 1 | 2 | 3.14 | 3.43 | 24
newknowledge_14 | 2 | 2 | 5 | 5 | 4 | 3 | 4 | 3.57 | 3.43 | 24
healthimpact_15 | 5 | 4 | 5 | 5 | 5 | 5 | 5 | 4.86 | 4.16 | 3
reducevariation_15 | 4 | 3 | 4 | 4 | 4 | 3 | 4 | 3.71 | 4.16 | 3
economicimpact_15 | 5 | 4 | 4 | 4 | 5 | 5 | 5 | 4.57 | 4.16 | 3
inaction_15 | 5 | 4 | 4 | 4 | 4 | 3 | 4 | 4.00 | 4.16 | 3
inequities_15 | 3 | 3 | 4 | 4 | 4 | 3 | 5 | 3.71 | 4.16 | 3
elsissues_15 | 3 | 4 | 5 | 5 | 4 | 1 | 5 | 3.86 | 4.16 | 3
newknowledge_15 | 3 | 4 | 5 | 5 | 5 | 4 | 5 | 4.43 | 4.16 | 3
healthimpact_16 | 5 | 4 | 5 | 5 | 2 | 5 | 5 | 4.43 | 3.80 | 13
reducevariation_16 | 5 | 3 | 5 | 5 | 2 | 5 | 5 | 4.29 | 3.80 | 13
economicimpact_16 | 5 | 4 | 4 | 4 | 4 | 5 | 5 | 4.43 | 3.80 | 13
inaction_16 | 5 | 4 | 4 | 4 | 2 | 3 | 4 | 3.71 | 3.80 | 13
inequities_16 | 3 | 3 | 4 | 5 | 2 | 1 | 4 | 3.14 | 3.80 | 13
elsissues_16 | 5 | 2 | 4 | 4 | 2 | 1 | 4 | 3.14 | 3.80 | 13
newknowledge_16 | 2 | 3 | 5 | 4 | 2 | 4 | 4 | 3.43 | 3.80 | 13
healthimpact_17 | 5 | 3 | 5 | 4 | 3 | 3 | 4 | 3.86 | 3.55 | 22
reducevariation_17 | 4 | 4 | 5 | 5 | 3 | 2 | 3 | 3.71 | 3.55 | 22
economicimpact_17 | 5 | 4 | 5 | 5 | 5 | 3 | 5 | 4.57 | 3.55 | 22
inaction_17 | 2 | 3 | 4 | 4 | 3 | 2 | 4 | 3.14 | 3.55 | 22
inequities_17 | 1 | 2 | 5 | 5 | 4 | 1 | 4 | 3.14 | 3.55 | 22
elsissues_17 | 1 | 2 | 5 | 4 | 3 | 1 | 4 | 2.86 | 3.55 | 22
newknowledge_17 | 2 | 3 | 5 | 4 | 4 | 3 | 4 | 3.57 | 3.55 | 22
healthimpact_18 | 5 | 3 | 5 | 3 | 4 | 3 | 5 | 4.00 | 3.67 | 21
reducevariation_18 | 5 | 3 | 5 | 1 | 4 | 3 | 4 | 3.57 | 3.67 | 21
economicimpact_18 | 5 | 3 | 5 | 2 | 4 | 3 | 5 | 3.86 | 3.67 | 21
inaction_18 | 5 | 2 | 4 | 2 | 4 | 2 | 5 | 3.43 | 3.67 | 21
inequities_18 | 5 | 2 | 5 | 2 | 4 | 1 | 5 | 3.43 | 3.67 | 21
elsissues_18 | 5 | 2 | 5 | 3 | 3 | 1 | 5 | 3.43 | 3.67 | 21
newknowledge_18 | 5 | 3 | 5 | 3 | 4 | 3 | 5 | 4.00 | 3.67 | 21
healthimpact_19 | 4 | 4 | 5 | 5 | 5 | 5 | 5 | 4.71 | 3.98 | 7
reducevariation_19 | 4 | 3 | 5 | 3 | 4 | 3 | 4 | 3.71 | 3.98 | 7
economicimpact_19 | 4 | 3 | 5 | 4 | 4 | 5 | 5 | 4.29 | 3.98 | 7
inaction_19 | 3 | 3 | 4 | 3 | 4 | 2 | 5 | 3.43 | 3.98 | 7
inequities_19 | 3 | 2 | 5 | 4 | 4 | 1 | 5 | 3.43 | 3.98 | 7
elsissues_19 | 3 | 4 | 5 | 4 | 4 | 1 | 5 | 3.71 | 3.98 | 7
newknowledge_19 | 4 | 3 | 5 | 5 | 5 | 5 | 5 | 4.57 | 3.98 | 7
healthimpact_20 | 3 | 3 | 5 | 5 | 5 | 5 | 5 | 4.43 | 3.80 | 13
reducevariation_20 | 3 | 5 | 4 | 5 | 4 | 5 | 5 | 4.43 | 3.80 | 13
economicimpact_20 | 1 | 4 | 4 | 4 | 4 | 2 | 5 | 3.43 | 3.80 | 13
inaction_20 | 2 | 3 | 4 | 4 | 4 | 1 | 5 | 3.29 | 3.80 | 13
inequities_20 | 2 | 4 | 4 | 4 | 4 | 1 | 5 | 3.43 | 3.80 | 13
elsissues_20 | 2 | 3 | 5 | 5 | 4 | 1 | 5 | 3.57 | 3.80 | 13
newknowledge_20 | 2 | 4 | 5 | 4 | 5 | 3 | 5 | 4.00 | 3.80 | 13
healthimpact_21 | 5 | 3 | 5 | 5 | 5 | 5 | 4 | 4.57 | 4.04 | 5
reducevariation_21 | 5 | 4 | 5 | 3 | 4 | 5 | 4 | 4.29 | 4.04 | 5
economicimpact_21 | 5 | 3 | 5 | 5 | 4 | 5 | 3 | 4.29 | 4.04 | 5
inaction_21 | 5 | 3 | 5 | 4 | 4 | 3 | 4 | 4.00 | 4.04 | 5
inequities_21 | 3 | 2 | 5 | 4 | 4 | 1 | 3 | 3.14 | 4.04 | 5
elsissues_21 | 5 | 2 | 5 | 4 | 4 | 1 | 3 | 3.43 | 4.04 | 5
newknowledge_21 | 5 | 3 | 5 | 5 | 5 | 5 | 4 | 4.57 | 4.04 | 5
healthimpact_22 | 3 | 5 | 5 | 4 | 3 | 5 | 4 | 4.14 | 3.69 | 20
reducevariation_22 | 5 | 4 | 5 | 4 | 2 | 5 | 4 | 4.14 | 3.69 | 20
economicimpact_22 | 4 | 4 | 5 | 4 | 4 | 5 | 5 | 4.43 | 3.69 | 20
inaction_22 | 3 | 4 | 5 | 3 | 2 | 5 | 4 | 3.71 | 3.69 | 20
inequities_22 | 1 | 3 | 5 | 4 | 2 | 1 | 4 | 2.86 | 3.69 | 20
elsissues_22 | 1 | 2 | 5 | 3 | 2 | 1 | 4 | 2.57 | 3.69 | 20
newknowledge_22 | 4 | 4 | 5 | 4 | 2 | 5 | 4 | 4.00 | 3.69 | 20
healthimpact_23 | 4 | 3 | 4 | 4 | 3 | 3 | 5 | 3.71 | 3.18 | 31
reducevariation_23 | 5 | 3 | 4 | 4 | 2 | 3 | 3 | 3.43 | 3.18 | 31
economicimpact_23 | 5 | 2 | 4 | 4 | 4 | 3 | 4 | 3.71 | 3.18 | 31
inaction_23 | 4 | 2 | 3 | 3 | 2 | 2 | 3 | 2.71 | 3.18 | 31
inequities_23 | 2 | 2 | 4 | 4 | 2 | 1 | 3 | 2.57 | 3.18 | 31
elsissues_23 | 4 | 2 | 4 | 3 | 2 | 1 | 3 | 2.71 | 3.18 | 31
newknowledge_23 | 5 | 2 | 4 | 4 | 2 | 3 | 4 | 3.43 | 3.18 | 31
healthimpact_24 | 3 | 4 | 5 | 5 | 5 | 5 | 5 | 4.57 | 3.71 | 18
reducevariation_24 | 4 | 3 | 4 | 4 | 4 | 3 | 4 | 3.71 | 3.71 | 18
economicimpact_24 | 3 | 3 | 4 | 4 | 4 | 4 | 4 | 3.71 | 3.71 | 18
inaction_24 | 1 | 3 | 4 | 4 | 4 | 4 | 5 | 3.57 | 3.71 | 18
inequities_24 | 1 | 2 | 4 | 5 | 4 | 1 | 5 | 3.14 | 3.71 | 18
elsissues_24 | 1 | 2 | 4 | 4 | 4 | 1 | 5 | 3.00 | 3.71 | 18
newknowledge_24 | 2 | 3 | 5 | 5 | 5 | 5 | 5 | 4.29 | 3.71 | 18
healthimpact_25 | 5 | 3 | 5 | 4 | 5 | 5 | 4 | 4.43 | 4.03 | 6
reducevariation_25 | 5 | 3 | 5 | | 5 | 5 | 4 | 4.50 | 4.03 | 6
economicimpact_25 | 5 | 4 | | 5 | 5 | 5 | 5 | 4.83 | 4.03 | 6
inaction_25 | 5 | 3 | 4 | 3 | 5 | 5 | 5 | 4.29 | 4.03 | 6
inequities_25 | 3 | 2 | 4 | 3 | 5 | 1 | 5 | 3.29 | 4.03 | 6
elsissues_25 | 3 | 1 | 5 | 3 | 4 | 1 | 3 | 2.86 | 4.03 | 6
newknowledge_25 | 5 | 2 | 5 | 3 | 5 | 5 | 3 | 4.00 | 4.03 | 6
healthimpact_26 | 4 | 4 | 4 | 5 | 4 | 3 | 4 | 4.00 | 3.24 | 30
reducevariation_26 | 5 | 4 | 4 | 4 | 3 | 5 | 3 | 4.00 | 3.24 | 30
economicimpact_26 | 3 | 3 | 3 | 4 | 3 | 3 | 3 | 3.14 | 3.24 | 30
inaction_26 | 3 | 3 | 3 | 4 | 3 | 3 | 3 | 3.14 | 3.24 | 30
inequities_26 | 3 | 3 | 3 | 5 | 3 | 1 | 1 | 2.71 | 3.24 | 30
elsissues_26 | 2 | 3 | 3 | 5 | 3 | 1 | 1 | 2.57 | 3.24 | 30
newknowledge_26 | 1 | 3 | 4 | 5 | 2 | 4 | 3 | 3.14 | 3.24 | 30
healthimpact_27 | 5 | 3 | 4 | 5 | 5 | 3 | 3 | 4.00 | 3.31 | 29
reducevariation_27 | 5 | 3 | 3 | 4 | 5 | 2 | 4 | 3.71 | 3.31 | 29
economicimpact_27 | 5 | 2 | 3 | 4 | 4 | 2 | 3 | 3.29 | 3.31 | 29
inaction_27 | 3 | 2 | 3 | 3 | 4 | 3 | 3 | 3.00 | 3.31 | 29
inequities_27 | 3 | 2 | 3 | 4 | 5 | 1 | 2 | 2.86 | 3.31 | 29
elsissues_27 | 3 | 2 | 3 | 4 | 4 | 1 | 1 | 2.57 | 3.31 | 29
newknowledge_27 | 3 | 2 | 4 | 4 | 5 | 4 | 4 | 3.71 | 3.31 | 29
healthimpact_28 | 1 | 4 | 4 | 5 | 4 | 5 | 3 | 3.71 | 3.37 | 28
reducevariation_28 | 5 | 4 | 3 | 4 | 4 | 5 | 3 | 4.00 | 3.37 | 28
economicimpact_28 | 1 | 3 | 3 | 4 | 4 | 5 | 4 | 3.43 | 3.37 | 28
inaction_28 | 2 | 3 | 3 | 4 | 3 | 3 | 3 | 3.00 | 3.37 | 28
inequities_28 | 2 | 2 | 3 | 5 | 4 | 1 | 4 | 3.00 | 3.37 | 28
elsissues_28 | 2 | 2 | 4 | 4 | 4 | 1 | 4 | 3.00 | 3.37 | 28
newknowledge_28 | 1 | 3 | 5 | 4 | 3 | 5 | 3 | 3.43 | 3.37 | 28
healthimpact_29 | 3 | 5 | 5 | 5 | 4 | 3 | 5 | 4.29 | 3.43 | 24
reducevariation_29 | 1 | 4 | 4 | 5 | 4 | 3 | 4 | 3.57 | 3.43 | 24
economicimpact_29 | 2 | 4 | 4 | 4 | 4 | 3 | 4 | 3.57 | 3.43 | 24
inaction_29 | 2 | 4 | 3 | 4 | 4 | 3 | 4 | 3.43 | 3.43 | 24
inequities_29 | 1 | 3 | 3 | 4 | 4 | 1 | 1 | 2.43 | 3.43 | 24
elsissues_29 | 1 | 2 | 3 | 5 | 4 | 1 | 2 | 2.57 | 3.43 | 24
newknowledge_29 | 2 | 4 | 5 | 5 | 4 | 4 | 5 | 4.14 | 3.43 | 24
healthimpact_30 | 5 | 4 | 5 | 5 | 5 | 3 | 3 | 4.29 | 3.82 | 12
reducevariation_30 | 5 | 4 | 5 | 4 | 4 | 3 | 4 | 4.14 | 3.82 | 12
economicimpact_30 | 3 | 3 | 4 | 4 | 4 | 3 | 2 | 3.29 | 3.82 | 12
inaction_30 | 3 | 4 | 4 | 4 | 4 | 2 | 3 | 3.43 | 3.82 | 12
inequities_30 | 5 | 4 | 5 | 5 | 4 | 1 | 3 | 3.86 | 3.82 | 12
elsissues_30 | 5 | 3 | 5 | 5 | 4 | 1 | 3 | 3.71 | 3.82 | 12
newknowledge_30 | 3 | 4 | 5 | 5 | 4 | 4 | 3 | 4.00 | 3.82 | 12