# Survey 2: Prioritization Survey

This survey asked respondents to rank a list of the 31 highest rated research needs resulting from previous survey findings. Respondents were asked to rate them from 1 (lowest) to 5 (highest) across seven AHRQ prioritization criteria. The 31 highest rated research needs were: conduct research on patient education, clinician education on community laproscopy results to patients, determine which patients are likely to benefit from surgery, develop standardized scales to assess quality of life for patients with noncyclic chronic pelvic pain, develop standardized diagnostic criteria, standardize diagnostic evaluations including history and physical, collect and analyze data to inform health care utilization and cost relationship, determine the accuracies of individual and combined diagnostic tests, assess the impact of noncyclic chronic pelvic pain on the use of health services, determine the role of musculoskeletal evaluations on resource use, conduct studies on self-management, standardize optimal surgical outcomes including followup interval (e.g., long-term outcomes), determine overall role of surgery, determine optimal followup to assess outcomes following surgical interventions, determine the role of idiopathic causes in the pathophysiology of noncyclic chronic pelvic pain, identify risk associations and women at risk for developing noncyclic chronic pelvic pain, document the treatment effect of diagnostic laproscopy, determine the direct and indirect costs that contribute to health care expenditures and economic impact, conduct studies on physiotherapy, conduct studies on cognitive behavior therapy, conduct studies on provider education, conduct studies on the management of patients who have failed pharmacologic treatment, determine optimal timing of surgical intervention, determine the role of surgical or pathological diagnosis on treatment outcomes, characterize and document the distribution and prevalence of comorbidities and conditions associated with noncyclic chronic pelvic pain, identify the most cost effective diagnostic and management strategies, characterize chronic pelvic pain subtypes, including the significance of differentiation between cyclic and noncyclic, characterize the distribution of symptom components (e.g., dyspareunia, dysmenorrhea, etc.) of noncyclic chronic pelvic pain, characterize the role of the patient-provider relationship on surgical outcomes, determine the role of condition-specific causes (e.g., endometriosis, pelvic adhesions, pelvic congestion, etc.) in the pathophysiology of noncyclic chronic pelvic pain, and determine patient dissatisfaction with care. The seven AHRQ prioritization criteria are: potential for significant health impact, potential to reduce variation in clinical practices, potential for significant economic impact, potential risk from inaction, potential to address inequities, potential to allow assessment of ethical, legal, social issues pertaining to the condition, and potential for new knowledge.