# Survey 1: Rating Survey

The project team compiled a list of 63 questions and recommendations for noncyclic chronic pain research based on input from stakeholders and the findings from the comparative effectiveness review. Survey respondents were asked to complete this survey to rate the importance of these research gaps and needs for future research on noncyclic chronic pelvic pain in women. The survey also gave respondents a chance to provide general feedback on the research questions and recommendations and offer additional research needs and gaps not already identified. Respondents were asked to answer an additional four questions about their interest and expertise in noncyclic chronic pelvic pain.