# Research Needs for Initial Rating

| Research Need | Source
1. | Develop standardized scales to assess quality of life for patients with noncyclic chronic pelvic pain. | Stakeholders
2. | Characterize chronic pelvic pain subtypes, including the significance of differentiation between cyclic and noncyclic. | CER
3. | Develop standardized diagnostic criteria. | CER
4. | Standardize diagnostic evaluations including history and physical. | Stakeholders
5. | Determine the accuracies of individual and combined diagnostic tests. | CER
6. | Develop standardized outcome measures and scales for quality of life and functional capacity. | Stakeholders
7. | Develop and validate a new pain assessment tool to capture the multidimensional experience of noncyclic chronic pelvic pain. | CER
8. | Develop and standardize an assessment tool to evaluate quality of life. | Stakeholders
9. | Determine the role of idiopathic causes in the pathophysiology of noncyclic chronic pelvic pain. | CER
10. | Determine the role of iatrogenic causes in the pathophysiology of noncyclic chronic pelvic pain. | CER
11. | Determine the role of condition-specific causes (e.g., endometriosis, pelvic adhesions, pelvic congestion, etc.) in the pathophysiology of noncyclic chronic pelvic pain. | CER
12. | Determine the role of trauma in the pathophysiology of noncyclic chronic pelvic pain. | Stakeholders
13. | Determine the role of genes and genetic susceptibility in the pathophysiology and pain related to noncyclic chronic pelvic pain. | Stakeholders
14. | Characterize the distribution of symptom components (e.g., dyspareunia, dysmenorrhea, etc.) of noncyclic chronic pelvic pain. | CER
15. | Characterize and document the distribution and prevalence of comorbidities and conditions associated with noncyclic chronic pelvic pain. | CER
16. | Distinguish between a comorbidity and an etiological factor in noncyclic chronic pelvic pain. | Stakeholders
17. | Determine the extent to which comorbidities modify treatment approaches and outcomes in noncyclic chronic pelvic pain. | CER
18. | Identify risk associations and women at risk for developing noncyclic chronic pelvic pain. | CER
19. | Conduct studies on physiotherapy. | CER
20. | Conduct studies on cognitive behavior therapy. | CER
21. | Conduct studies on psychological counseling. | CER
22. | Conduct studies on acupuncture. | CER
23. | Conduct studies on transcutaneous electrical nerve stimulation (TENS). | CER
24. | Conduct studies on self-management. | Stakeholders
25. | Conduct studies on provider education. | Stakeholders
26. | Conduct studies on patient education. | Stakeholders
27. | Conduct studies on diet therapy. | Stakeholders
28. | Conduct studies on integrative medicine. | Stakeholders
29. | Conduct studies on the Centering Model. | Stakeholders
30. | Conduct studies on nutritional and herbal supplements. | Stakeholders
31. | Conduct studies on the nonhormonal agent, tanezumab (anti-NGF monoclonal antibody RN624). | CER
32. | Conduct studies on the nonhormonal agent, gabapentin (Neurontin). | Stakeholders
33. | Conduct studies on opioid analgesics. | Stakeholders
34. | Conduct studies on steroid injections. | Stakeholders
35. | Conduct studies on lidocaine injections. | Stakeholders
36. | Conduct studies on botox injections. | Stakeholders
37. | Conduct studies on the nonhormonal agent, duloxetine (Cymbalta). | Stakeholders
38. | Conduct studies on muscle relaxants (administered vaginally or rectally). | Stakeholders
39. | Conduct studies on gabapentin as a preoperative agent. | Stakeholders
40. | Conduct studies on the optimization of hormonal agent administration including timing, dosing, and duration. | CER
41. | Conduct studies on the appropriate selection of patients for hormone therapy. | CER
42. | Conduct studies on the management of patients who have failed pharmacologic treatment. | CER
43. | Determine the optimal timing of surgical intervention. | CER
44. | Determine which patients are likely to benefit from surgery. | CER
45. | Standardize optimal surgical outcomes including followup interval (e.g., long-term outcomes). | CER
46. | Determine the role of surgical or pathologic diagnosis on treatment outcomes. | CER
47. | Determine the role of hysterectomy with or without oophorectomy. | CER
48. | Determine the overall role of surgery. | Stakeholders
49. | Determine optimal followup to assess outcomes following surgical interventions. | Stakeholders
50. | Characterize the role of the patient-provider relationship on surgical outcomes. | Stakeholders
51. | Examine the role of magnetic resonance imaging (MRI) before laparoscopy. | Stakeholders
52. | Document the treatment effect of diagnostic laparoscopy. | CER
53. | Assess the impact of noncyclic chronic pelvic pain on the use of health services. | CER
54. | Identify the most cost effective diagnostic and management strategies. | CER
55. | Determine the role of musculoskeletal evaluations on resource use. | Stakeholders
56. | Establish a distinctive administrative diagnostic code for noncyclic chronic pelvic pain. | Stakeholders
57. | Collect and analyze data to inform health care utilization and cost relationship. | Stakeholders
58. | Determine the direct and indirect costs that contribute to health care expenditures and economic impact. | Stakeholders
59. | Conduct additional research specifically on patients who have had multiple interventions (e.g., multiple laparoscopies). | Stakeholders
60. | Conduct additional research specifically on patients who have undergone repeat diagnostic imaging (e.g., computed tomography scans). | Stakeholders
61. | Determine costs related to diagnostic imaging in patients with noncyclic chronic pelvic pain. | Stakeholders
62. | Determine patient dissatisfaction with care. | Stakeholders
63. | Characterize patient healthcare-seeking for alternative treatments. | Stakeholders

Abbreviations: CER=comparative effectiveness review