# Stakeholder Conference Call Summary

## Participants

- Anna Albrecht, MPH (Director, Wellness Initiatives, Women’s Health Foundation, Chicago, IL)
- Dee Hartmann, DPT, PT (Treatment of Women’s Health and Chronic Pelvic Dysfunction, Chicago, IL)
- Linda McGowan, PhD, MSc (Senior Lecturer, University of Manchester, Manchester, UK)
- Eric Wall, MD, MPH (Senior Medical Director, Qualis Health, Seattle, WA)
- Priscilla Abercrombie, PhD, RN, NP (Nurse Practitioner, Department of Obstetrics, Gynecology, and Reproductive Sciences, University of California San Francisco, San Francisco, CA)
- Jane Daniels, MSc (Department of Obstetrics & Gynaecology, Birmingham Women’s Hospital, UK
- Esther Eisenberg, MD, MPH (Professor, Department of Obstetrics and Gynecology, Vanderbilt University Medical Center, Nashville, TN)
- Cynthia Neville, DPT, PT, WCS, BCB-PMD (Director, Women’s Health Services, Brooks Rehabilitation, Jacksonville, FL)
- Steve Phurrough, MD, MPA (Chief Operating Officer and Senior Clinical Director, Center for Medical Technology and Policy, Baltimore, MD)
- John Steege, MD (Chief, Division of Gynecology, University of North Carolina, Chapel Hill, NC)
- Frank Tu, PMD, MPH (Director, Division of Gynecological Pain and Minimally Invasive Surgery, NorthShore University Health System, Chicago, IL)

## Introductions and Purpose

The purpose of this call was to review and discuss the preliminary list of research gaps identified in the Comparative Effectiveness Review, “Noncyclic Chronic Pelvic Pain Therapies for Women” and to solicit stakeholder input on key research gaps and questions of relevance to CPP.

Following brief introductions, Dr. Reynolds facilitated a discussion using the outline of research needs included in the meeting agenda that was distributed previously to call participants.

Specifically, call participants were asked to: 1) review and comment on the initial list of research gaps and; 2) suggest potential research topics and questions not included in the initial list of research gaps.

## Stakeholder Comments

Stakeholder comments and suggestions are summarized below:

1. Definition and standardization of CPP
  - The stakeholders noted that CPP definitions are arbitrary agreed that standardization of the definitions for CPP is important.
  - The stakeholders also stated that there is a lack of consensus for key descriptors and terminology for CPP (e.g., “pelvic”, “duration” and “chronicity”).
  - The stakeholders noted that there is a need for standardized scales to assess quality of life for patients with CPP.
  - The stakeholders also stated that patient history and patient questionnaires are important tools for assessing and diagnosing women with pelvic pain
  - Is there any value to using unrelated procedures or conditions to evaluate the quality of pain?
  - The stakeholders noted that characterization of the pelvic pain including location, duration, subtypes is important.
  - In clinical practice, noncyclic and cyclic pain mixed. What is the qualitative perspective?
2. Outcome measures
  - Stakeholders agreed that standardized outcome measures are needed, specifically for quality of life and functional capacity.
  - CPP outcome measures and scales should be established and validated.
  - Stakeholders added that reliable measures of patient-reported outcomes would be beneficial for research of therapies for CPP.
  - Is there a way to capture data about internal pain?
  - Stakeholders suggested that standardized lists be focused on the needs of payers, patients, and clinicians in addition to researchers.
3. Research quality and study design
  - Call participants agreed that good quality, appropriately designed clinical trials of CPP are needed to build a robust and useful body of literature.
  - Stakeholders added that the methodologies that support evaluation of multidimensional treatments are important.
4. Etiology and co-morbidities
  - Stakeholders suggested that understanding disease pathophysiology and elucidation of the relationship between pain and disease is critical to evaluation and management of CPP.
  - Where possible, research should seek to sort out what is a co-morbidity and what is a cause.
  - What is the role of myofascial dysfunction and musculoskeletal problems (e.g. low back pain, hip pain, pelvic and abdominal visceral pain) in CPP?
  - Stakeholders recommended that future research investigate the role of trauma to CPP diagnosis, etiology, and treatment. Trauma, both iatrogenic and external, should be listed as a separate category for research needs.
  - Stakeholders agreed that the role of sexual dysfunction in CPP is an important topic for future research.
  - Stakeholders emphasized the value of patient history and proper physical examination in CPP.
  - Research to improve the understanding of the relationship between certain events early in life (e.g., abuse, childhood urinary tract infection, external trauma) and the incidence of CPP would be helpful.
  - Stakeholders recommended that future research examine co-morbidities in terms of other pain syndromes.
  - Stakeholders added that psychological attributes including fear, avoidance, and pain catastrophizing should be further examined as relevant co-morbidities or etiological factors.
  - Stakeholders suggested that genetic susceptibility be considered.
5. Non-surgical/non-pharmacologic treatment
  - The stakeholders agreed that there is a need for research on non-surgical/non-pharmacological strategies to manage CPP.
  - In addition to those identified, stakeholders suggested that self-management, and education (for providers and patients) be added to list of non-surgical/non-pharmacological treatments.
  - One stakeholder noted that research on mechanisms of pain using functional magnetic resonance imaging (fMRI) may offer valuable insights for CPP.
  - Patients are often unsatisfied with care and seek alternative treatments.
    In addition to those identified, stakeholders suggested that diet therapy, integrative medicine, and the centering model be included.
  The stakeholders noted that herbal and other nutritional supplements are widely used and should therefore be researched.
6. Pharmacologic treatment
  - In addition to hormonal therapies, the list of research needs should include opioid analgesics, steroid injections, lidocaine injections, botox injections, cymbalta, and muscle relaxants (vaginally and rectally administered).
  - Stakeholders agreed that studies of gabapentin would also be useful.
  - What is the role of gabapentin on pain when given preoperatively?
7. Surgical treatment
  - Stakeholders noted that surgery has not been shown to be successful.
  - Long term followup of surgery treatment is needed to assess outcomes.
  - What is the role of the patient provider relationship on outcomes?
  - What is the role of MRI before laparoscopy?
8. Impact and resource utilization
  - Stakeholders agreed that in order to investigate impact and resource use, a standard classification is needed.
  - There is not diagnostic code for CPP in the United Kingdom.
  - Stakeholders suggested that claims analysis or charge data for CPP would be interesting.
  - Stakeholders agreed that information to inform economic analysis, health care utilization, and cost relationship is important.
  - Research on health care expenditures, and missed work due to CPP has the potential to highlight the prevalence and impact of CPP.
  - Stakeholders agreed that it would be interesting to know more about patients who have had multiple laparoscopies and repeat CT scans.
  - Stakeholders suggested that musculoskeletal evaluations are the least expensive and simple exam that should be done.
  - Stakeholders agreed that the health care costs related to imaging in this patient population is significant
9. Other
  - Focus on research that translates to clinical practice (e.g., in the context of practice-based research networks).
  - Use research to educate and increase awareness among a range of health care providers (e.g., physician assistants).
  - Examine the variation in practice patterns and choice of treatment/intervention based on provider specialty. For example, how do urologic, gynecologic, colorectal specialists differ in diagnosis, approach, and management of patients? How do outcomes vary for patients treated by different clinical specialists?
  - What is the role of self-management for CPP patients?
  - What is the role of self-diagnosis? One stakeholder gave the example of somatoform disorder.
  - Stakeholders agreed that primary care providers would benefit from improved awareness of what CPP is and how best to manage/refer patients.

## Next Steps

- Prioritize refined list of gaps with stakeholders
- Review list of high priority research needs with stakeholders
- Reprioritize list of top tier/high priority needs with stakeholders