# Translation of Evidence Gaps From CER Into Research Needs

1. Definition and standardization of CPP:
  a. Establish and validate a standardized definition of CPP, including differentiation between cyclic and non-cyclic subtypes
  b. Establish and validate standardized diagnostic criteria for CPP
  c. Standardize diagnostic evaluations for patients potentially with CPP
  d. Estimation of the accuracy of individual and combinations of diagnostic tests for CPP
  e. Develop and validate a new pain assessment tool to capture the multidimensional experience of CPP
2. Outcome measures
  a. Use of standardized outcome measures, such as those recommended by the IMPACT consensus
3. Research Quality and study design
  a. Use of appropriately designed clinical trials, following CONSORT guidelines
  b. Use of placebo control
  c. Appropriate power/sample size for primary outcome and/or subgroup analyses
4. Etiology and co-morbidities
  a. Understanding pathophysiology of the condition and relationship between pain and disease
    i. Idiopathic/de novo
    ii. Iatrogenic causes
    iii. Condition-specific causes (endometriosis, pelvic adhesions, pelvic congestion etc.)
  b. Analyses of distribution of the various symptom components of non-cyclic CPP, including dyspareunia, dysmenorrhea, etc.
  c. Document the distribution and prevalence of various co-morbidities and associated conditions that co-occur with CPP
  d. Use of specific standardized and validated tools to inform our understanding of the true prevalence of conditions reported to co-occur with CPP
  e. Analyses examining the extent to which comorbidities modify treatment approaches and outcomes in CPP
  f. Identify risk associations and women at risk for developing CPP
  g. Develop preventive strategies
5. Non-surgical/non-pharmacologic treatment
  a. Systematically assess the role in CPP treatment for:
    i. Physiotherapy
    ii. Cognitive-behavior therapy
    iii. Psychological counseling
    iv. Acupuncture
    v. TENS
6. Pharmacologic treatment
  a. Studies of non-hormonal agents, such as tanezumab
  b. Additional studies on hormonal agents, with focus on:
    i. Optimization of administration, including timing, dosing, duration
    ii. Appropriate selection of patients for hormone therapy
  c. Treatment of pharmacologic failures
7. Surgical treatment
  a. Determine the optimal timing of surgical intervention
  b. Determine which patients are likely to benefit from surgery
  c. Standardize optimal surgical outcomes
  d. Determine the role of surgical or pathologic diagnosis (including diagnostic laparoscopy) for the effective treatment of CPP
  e. Further study on the role of hysterectomy with or without castration for the treatment of CPP
  f. Other specific procedures/techniques
8. Impact and resource utilization
  a. Assessment of the impact of CPP on the use of health services
  b. Economic analysis to determine the most cost effective diagnostic and management strategies for CPP