# Ongoing and Recently Completed Studies

Study Name, Location Trial Identifier Sponsor | Inclusion/Exclusion Criteria | Interventions | Start Date—Est. Completion Date Est. Enrollment
Female Chronic Pelvic Pain, Denmark NCT01255345 Copenhagen University Hospital at Herlev | Inclusion Criteria:; - Women ≥ 18 years; - Living in Copenhagen Country (Region H); - Capable of reading, writing and speaking Danish; Exclusion Criteria:; - Pain limited solely to the perineal skin or introitus (vulvodynia); - Pregnancy, cancer, active pelvic inflammatory disease; - Operation in the pelvic during the last 6 months; - Cognitively impaired individuals | Physiotherapeutic examination of abnormal muscular findings, i.e. tonus, elasticity and strength, in the pelvic area connected to female CPP | January 2011 – December 2012 2500
Observational Study of Control Participants for the MAPP Research Network, United States NCT01098292 National Institute of Diabetes and Digestive and Kidney Diseases | Includes health controls and positive controls. | N/A | December 2009 -- December 2012 630
Global Study of Women’s Health, United States NCT00849173 Eunice Kennedy Shriver National Institute of Child Health and Human Development | Inclusion Criteria:; - Premenopausal female 18 to 45 years of age; - Attending for her first diagnostic laparoscopy or for laparoscopy for tubal sterilisation; - Has no previous history of endometriosis diagnosis through surgery; Exclusion Criteria:; - Already has a surgically-confirmed diagnosis of endometriosis; - Aged less than 18 or greater than 45; - Aged 18–45 but post-menopausal | N/A | February 2009 -- NR 2950
Addition of Pudendal Blocks to Pelvic Floor Physical Therapy for the Treatment of Pelvic Floor Tension Myalgia, United States NCT00928564 University of California, Irvine | Inclusion Criteria:; - Non-pregnant women over the age of 18 with the diagnosis of pelvic floor tension myalgia that are naive to pelvic floor physical therapy.; - Able to provide informed consent.; - Subjects must be willing to accept randomization.; Exclusion Criteria:; - Previously treated with physical therapy.; - An allergy to any component within the pudendal block.; - Bleeding disorders.; - Active vaginal infection.; - Inability to complete the questionnaires.; - Inability to read English (validated questionnaires are available in English only).; - Inability to complete the follow-up visits. | Active: Drug: Pudendal block: 8ml of 0.5% bupivicaine, 1ml of 10mg/ml triamcinolone, 1ml of 8.4% sodium bicarbonate for a total volume of 10ml. Five ml will be used at each block site. Placebo: 5ml of saline at each block site. | April 2009 – June 2011 140
Follow-up Strategies for Improved Postoperative Recovery After Benign Hysterectomy, Sweden NCT01526668 University Hospital, Linkoping | Inclusion Criteria:; - Women between 18 and 60 years of age.; - Women who are scheduled for vaginal or abdominal total or subtotal hysterectomy for benign gynecological diseases (including cervical dysplasia).; - Women who understand and speak Swedish fluently.; - Women who give signed informed consent to participate in the study.; - Women who have access to a telephone and/or internet.; Exclusion Criteria:; - Women where the hysterectomy is carried out in association with surgery for genital prolapse; - Women with genital malignancies (does not include cervical dysplasia).; - Women where the operation is planned or expected to comprise more than the hysterectomy with or without unilateral salpingooophorectomy and appendectomy en passant.; - Women with previous bilateral salpingooophorectomy.; - Women who are physically disabled to a degree so that mobilization postoperatively cannot be expected as for a normal individual.; - Women who are mentally disabled to a degree so she cannot complete the forms in the study or understand the tenor of the participation or it is considered doubtful from an ethical point of view to participate.; - Women with psychiatric disease or is on medication for severe psychiatric disease so that the physician consider participation in the study unsuitable.; - Women with current drug or alcohol abuse. | Behavioral: Follow-up strategy Comparison of different follow-up strategies | October 2011 -- January 2015 600
Transcranial Direct Stimulation in Chronic Pelvic Pain, United States NCT01143636 Spaulding Rehabilitation Hospital | Inclusion Criteria:; - Providing informed consent to participate in the study; - 18 to 64 years old; - Having symptoms of pelvic pain for more than 6 months with an average of 3 on a 0–10 VAS scale (for pelvic pain subjects only); - No history of or current genitourinary tuberculosis as self reported; - No history of urethral cancer as self reported; - No history or current bladder malignancy, high grade dysplasia or carcinoma in situ as self reported; - No occurrence of ovarian, vaginal or cervical cancer in the previous 3 years as self reported; - No current vaginal infection as self reported; - No active herpes in previous 3 months as self reported; - No antimicrobials for urinary tract infections in previous 3 months as self reported; - Never treated with cyclophosphamide as self reported; - No radiation cystitis as self reported; - No neurogenic bladder dysfunction (due to a spinal cord injury, stroke, Parkinson’s disease, multiple sclerosis, spina bifida or diabetic cystopathy) as self reported; - Absence of bladder, ureteral or urethral calculi for previous 3 months as self reported; - No urethritis for previous 3 months as self reported; - No urethral dilatation, cystometrogram, bladder cystoscopy with full anesthesia or bladder biopsy in previous 3 months as self reported; - Must not be pregnant; - Eligible to MRI according to MRI screening checklist; - No contraindications to Transcranial Direct Stimulation:; - No history of alcohol or drug abuse within the past 6 months as self reported; - No use of carbamazepine as self reported; - Does not have severe depression (with a score of >30 in the Beck Depression Inventory); - No history of neurological disorders as self reported; - No history of unexplained fainting spells as self reported,; - No history of head injury resulting in more than a momentary loss of consciousness as self reported; - Have had no neurosurgery as self reported; - No history of psychological disorders as self reported; - Must have the ability to feel pain as self reported | Transcranial Direct Current Stimulation | April 2010 - April 2012 68
Duloxetine for the Treatment of Chronic Pelvic Pain, United States NCT01451606 University of Maryland; Eli Lilly and Company | Inclusion Criteria:; - Premenopausal adult women, aged 18–30; - Have chronic pelvic pain, as defined by the American College of Obstetrics and Gynecology; - Able to read and speak English; Exclusion Criteria:; - Chronic Pelvic Pain only presenting in low back or vulva, or only present during menstruation or vaginal intercourse; - Self-report or documentation that all CPP sites were attributed by a prior physician to IBS, IC/PBS, urinary tract infection, urinary stones, inflammatory bowel disease (ulcerative colitis or Crohn’s disease), cancer or shingles.; - Currently pregnant or lactating; - A primary psychiatric diagnosis of major depression or history of suicide attempt as assessed by medical history. Also, those who would be considered to have Major Depressive Disorder (MDD) on the basis of DSM-IV criteria will excluded, as well as those selecting “3” or “4” on item #9 of the BDI (suicidal ideation).; - A history of bipolar disorder; - A history of seizure disorders; - Orthostatic Hypertension; - Exclusions based on the effects of duloxetine:; ○ Known hypersensitivity to duloxetine or the inactive ingredients in Cymbalta;; ○ Treatment with an monoamine oxidase inhibitor (MAOI) within 14 days of randomization, or potential need to use an MAOI during the study or within 5 days of discontinuation of the drug;; ○ Treatment with cytochrome P450 enzyme inhibitors;; ○ Uncontrolled narrow-angle glaucoma;; ○ Concurrent use of thioridazine; ○ Renal Impairment (serum creatinine of 1.5 or greater); ○ History of jaundice or hepatomegaly; ○ Hepatic Insufficiency (elevated AST, ALT, bilirubin, or Alkaline Phosphatase), tested at the screening period, after the first week of study medication, and again at the midpoint of the study.; - Participants who are taking SSRIs, SSNRIs, MAOIs, or tricyclics within 14 days of randomization will be excluded.; - Participants who currently meet DSM-IV diagnostic criteria for Alcohol Abuse or Dependence; - Weight exceeding 285 pounds; - Hyponatremia, as determined by blood test results | Drug: Duloxetine 30 mg dose once daily, administered orally for 1 week, 60 mg dose once daily, administered orally for 5 weeks, 30 mg dose once daily, administered orally for 1 week | June 2011 -- September 2012 120
Investigation and Treatment of Central Nervous System Dysfunction in Chronic Pelvic Pain, United States 5R21DK081773-03 Spaulding Rehabilitation Hospital; National Institute of Diabetes and Digestive and Kidney Diseases | NR | NR | September 2009--July 2012
Multi-Disciplinary Approach to the Study of Chronic Pelvic Pain (MAPP), United States 5U01DK082344-04 National Institute of Diabetes and Digestive and Kidney Diseases | NR | NR | September 2008—June 2013
Psychosocial Treatment for Gynecology Patients with Co-Morbid Depression and Pain, United States 5K23MH079347-05 University of Rochester; National Institute of Mental Health | NR | NR | March 2007—May 2012
Guided Self-Help for Women with Chronic Pelvic Pain (CPP) in Primary Care, United Kingdom ISRCTN95540596 National Institute for Health Research (NIHR) (UK)—Research for Patient Benefit (RfPB) Programme (ref:PB-PG-0408-16192; University of Manchester (UK) | Inclusion Criteria:; - Women ≥ 18 years; - Pelvic pain greater than 3 months duration; - Pain not necessarily related to menstrual cycle or sexual activity; - Has a common diagnosis which falls under the umbrella of CPP; - Has a symptom profile attributed to CPP, in the absence of a diagnosis; Exclusion Criteria:; - Pregnancy or within 12 months delivery; - Serious underlying pathology; - Insufficient English to engage in self-help; - Participation in other pain management research | Pilot trial of an evidence-based self-care guide for women with CPP that will be facilitated by their GP. | November 2010—December 2011 140
The Action of Gabapentin for the Management of Chronic Pelvic Pain in Women (GaPP), United Kingdom ISRCTN70960777 University of Edinburgh (UK) | Inclusion Criteria:; - Women aged between 18–50; - Consented to a routine diagnostic laparoscopy; - Pelvic pain of > 6 months; - Pain located within the true pelvis or between and below anterior iliac crests, associated functional disability; - No obvious pelvic pathology; Exclusion Criteria:; - Known pelvic pathology e.g. endometriosis, cyst; - Undergoing major surgery e.g. hysterectomy; - Estimated Glomerular Filtration Rate (eGFR) >60 | Gabapentin versus placebo. 300mg dose increasing in weekly increments to a maximum dose of 2700mg if pain has not been reduced by 50% each week. Daily administration (TID) and by oral capsule, treatment given for 6 months. | February 2012—November 2013 60

Abbreviations: BTXA = Botulinum Toxin Type A; CPP = chronic pelvic pain; DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, Fourth edition; EMG = electromyogram; GnRH = gonadotropin releasing hormone; HAM-A = Hamilton anxiety Scale; HAM D = Hamilton depression Scale; HCV = hepatitis C; HTPMFD =High Tone Pelvic Floor Dysfunction; MRI = magnetic resonance imaging; PID = pelvic inflammatory disease; VAS = visual analog scale; NR = not reported.