# Literature Search

Table A1 PubMed search results

Search terms | | Results
#1 | “chronic pelvic pain” | 2,113
#2 | chronic OR recurrent OR recurring OR chronic disease[mh] OR noncyclic OR non-cyclic OR mixed | 1,204,037
#3 | “pelvic pain” OR pelvic pain[mh] | 8,796
#4 | (musculoskeletal diseases[mh] OR myofascial[tiab]) AND (pelvic[tiab] OR pelvis[tiab] OR pelvis[mh] OR pelvic pain[tiab]) | 7,698
#5 | #1 OR (#2 AND (#3 OR #4)) AND eng[la] AND humans[mh] AND 1990:2012[dp] | 2,521
#6 | #5 NOT (case reports[pt] OR letter[pt] OR comment[pt] OR editorial[pt] OR review[pt] OR meta-analysis[pt] OR practice guideline[pt]) | 1,389

Last updated 3/29/2012; n=109 since last search for CER (5/3/2011). Key: [mh] Medical Subject Heading; [la] language; [pt] publication type; [dp] publication date; [tiab] title/abstract word.