# Acronyms and Abbreviations

ADL: Activities of daily living
AHRQ: Agency for Healthcare Research and Quality
BDI: Beck Depression Inventory
CI: Confidence interval
CINAHL: Cumulative Index of Nursing and Allied Health Literature
CPP: Noncyclic chronic pelvic pain
EPC: Evidence based Practice Center
g,G: Group
GnRH: Gonadotropin releasing hormone
IBS: Irritable bowel syndrome
IHS: International Headache Society
IC: Interstitial cystitis
IC/PBS: Interstitial cystitis/Painful bladder syndrome
IMMPACT: Initiative on Methods, Measurement, and Pain Assessment in Clinical Trials
KQ: Key question
LUNA: Laparoscopic utero-sacral nerve ablation
MPQ: McGill Pain Questionnaire
MRI: Magnetic resonance imaging
n, N: Number
NR: Not reported
OCP: Oral contraceptive pills
OR: Odds ratio
PBS: Painful bladder syndrome
PET: Positron Emission Tomography
QOL: Quality of life
RCT: Randomized controlled trial
RR: Relative risk
SERM: Selective estrogen receptor modulator
SOE: Strength of evidence
TENS: Transcutaneous Electrical Nerve Stimulation
TEP: Technical Expert Panel
VAS: Visual analog scale