# Results

## Stakeholder Engagement

We enlisted a total of eight stakeholders in the identification and/or prioritization of research needs related to the use of breathing techniques in the treatment of asthma. Four individuals took part in both the identification and prioritization of research questions, two individuals only participated in helping to identify and refine evidence needs, and two individuals only participated in the prioritization of research questions.

Figure 3 details the flow of stakeholders through the process. Of the twelve stakeholders invited to participate in one-on-one interviews to help identify evidence gaps; six agreed to participate. They included two academic researchers whose primary research studies were included in the CER, one federal employee working on asthma-related programs, one practicing pediatric allergist and immunologist, a licensed Naturopathic physician, and a registered respiratory therapist-neonatal pediatric specialist who also serves on the board of directors for a national asthma patient advocacy organization.

Figure 3 Participant flow diagram

Figure 3 depicts the flow of participants throughout the study. Twelve stakeholders were invited for one-on-one interviews of which six accepted our invitation; the others declined to participate (n=3) or did not respond (n=3). Five of the six moved forward with the online prioritization questionnaire (one stakeholder was recused from participating) and we invited an additional 10 stakeholders to take the online prioritization questionnaire (for a total of 15 invited stakeholders). Only six stakeholders completed the questionnaire, the others did not complete the activity (n=1), recused themselves from the activity (n=3), were unavailable (n=1) or did not respond (n=4).

None of the identified stakeholders had a conflict judged to preclude participation in the process. Disclosed conflicts included serving as a consultant to several medical technology and pharmaceutical companies, involvement with professional organizations focused on respiratory care, funded research from the National Heart, Lung, and Blood Institute, and being a curator at a college of natural medicine and being involved with two organizations focused on the Buteyko Breathing method.

Three individuals declined our invitation to participate in one-on-one interviews. One felt she was not familiar enough with the topic to be of assistance (Professor of Medicine in a Division of Pulmonary and Critical Care Medicine). Another individual who worked for a large nonprofit organization that focused on asthma patient advocacy felt that she was not an appropriate fit for this project. After further discussion, she felt it was not appropriate for someone who was not a scientist to participate. Lastly, a representative from one of the institutes of the National Institutes of Health (NIH) said that her Division was reluctant to participate in projects which would be making research recommendations to agencies such as the NIH; as if they would be advising themselves. We did not receive a response from the remaining three stakeholders despite more than one invitation sent.

After conducting the one-on-one interviews, revising and adding evidence needs, and reframing the needs as research questions, we sent the revised list via e-mail to five of the six stakeholders for their feedback on the revisions. One stakeholder who participated in a one-on-one interview felt she would not be appropriate to continue working with us to prioritize the research questions given her limited knowledge of the field. We received e-mail responses from two of the five stakeholders; both stated that they felt the list was complete.

In addition to these five stakeholders, we invited another 10 individuals to prioritize the list of research questions. Individuals were identified and invited on a rolling basis. We attempted to maximize engagement by sending additional invitations as particular stakeholders either declined to participate or we received no response after multiple attempts. Ultimately, six stakeholders completed the online prioritization questionnaire (four original stakeholders and two new stakeholders).

On average, the stakeholders completed the online prioritization questionnaire in 17 minutes (range: 7 to 49 minutes). One stakeholder started the questionnaire but never submitted his responses despite several e-mail requests. The six stakeholders who completed the questionnaire included two academic researchers, three practitioners (naturopathic medicine, allergist/immunologist, and respiratory therapist) and a director of patient advocacy for a state-based asthma control program. Of the additional eight stakeholders we invited to participate in the prioritization exercise, three individuals responded that they were not experts in the area and did not feel comfortable participating (despite being referred by colleagues), one individual was too busy to participate, and four individuals were not responsive after multiple email invitations.

## Research Needs

The original CER identified a number of research gaps that provided a starting point for the development and prioritization of research questions for future studies. Below is a summary of these research gaps categorized by the most relevant element of the PICO framework (Table 1).

Table 1 Future research needs identified by review of the comparative effectiveness review

Category | Research Needs
Population | - Studies with large sample sizes; - Studies in population subgroups (e.g., non-White, children, older adults); - Studies in populations applicable to the U.S. healthcare system; - Determination of the optimal candidates for treatment with breathing techniques (e.g., those without well-controlled asthma)
Intervention | - Determination of optimal intensity and duration of treatment; - Studies on expiratory muscle training and how this intervention differs from IMT; - Studies on breathing physical therapy; - Studies of other emerging breathing techniques and technologies; - Studies of strategies to optimize benefits and minimize harms, such as additional lifestyle modifications and treatment components; - Studies of breathing techniques with a component targeting autonomic arousal (e.g., relaxation); - Studies of breathing techniques with a component requiring the delay of reliever use medication; - Replication of previous studies to establish effectiveness; - Studies to determine theoretical basis of breathing techniques (i.e., nonhyperventilation reduction breathing techniques); - Standardized asthma and asthma-related terms to characterize interventions and explore effectiveness of specific elements of the intervention; - Standardized interventions and level of detail reported (e.g., route, region, timing, etc.); - Interventions consistent with the standard of care in the United States by including asthma treatment with medications and education
Comparator | - Head-to-head comparison trials (i.e., comparative effectiveness research such as IMT versus Buteyko breathing); - Intensity-matched control groups
Outcome | - Standardized asthma outcome reporting including the requirement of reporting asthma symptoms; - Additional evaluation of breathing techniques to determine their safety; - Long-term evaluation of outcomes, including conducting an extended followup evaluation of previous studies

Abbreviation: IMT: inspiratory muscle training

### Additional Future Research Needs Identified Through Interviews

During the individual interviews, six stakeholders reviewed and commented on the list of preliminary FRN (Table 1) identified from the original CER. One stakeholder also provided detailed written comments. A number of additional themes and specific evidence needs emerged in this stage. Based on these discussions, the project team revised the list of research needs, including reframing them all as research questions. In total, 37 future research questions were identified (Appendices D and E). The majority (k=21) of the additional research gaps related to issues considered to be out-of-scope of the original CER (e.g., understanding the mechanisms by which specific breathing techniques might affect asthma outcomes [including autonomic responses]; Appendix E). The remaining 16 research questions were considered to be within the scope of the original CER (Appendix D). Most of these questions related to the need for more studies that targeted specific subgroups such as children and adolescents, those who are not adherent to usual asthma treatment, and those with varying levels of asthma severity and studies that evaluated specific breathing techniques or multicomponent interventions.

### Methods-Related Research Needs

Six methods-related issues and overarching questions were detailed in the original CER and were confirmed as important considerations throughout the one-on-one interviews. These issues were not included in the prioritization questionnaire, but were noted as extremely important issues in this area of research by all stakeholders. These issues were:

1. Trials of head-to-head comparisons of specific breathing techniques (matched for intensity), other lifestyle modifications, or medication regimens;
2. Studies with larger sample sizes, including multicenter trials;
3. Studies among specific population subgroups (e.g., non-White, children, older adults, individuals diagnosed with exercise-induced asthma) or heterogeneous trials with outcomes presented by subgroups;
4. Replication of or long-term followup of previous studies with positive effects or that use a standard breathing technique to further establish effectiveness;
5. Standardized intervention details reporting, including: specific breathing technique(s) practiced (e.g., shallow versus deep breathing, length of breath hold, nasal versus mouth breathing); and
6. Standardized outcomes reporting, including: asthma symptoms (e.g., wheezing, severity of asthma); pulmonary function (e.g., breathing rate, airway inflammation, daily PEF and PFV); cardiovascular outcomes (e.g., heart rate); quality of life (e.g., stress, anxiety); medication use; harms; psychosocial measures (e.g., self-efficacy)

### Prioritization of Future Research Needs

Based on the methods described above, we organized the future research needs questions that were considered to be within the scope of the original CER into three categories: high-priority research questions (n=5), medium-priority research questions (n=3), and low-priority research questions (n=8). Four out of the five highly prioritized questions also received a high-level of consensus among stakeholders (i.e., more than half of the stakeholders allocated at least one vote to these questions). These four questions are indicated with an asterisk (*) below.

## High-Priority Research Questions and Study Design Considerations

The following is the final set of high-priority research questions. Only the research questions considered to be within the scope of the original CER that received six or more votes are included in this discussion. Although the research questions are listed from 1 to 5; research questions 1 to 3 had identical levels of ranking (i.e., eight stars total), research question 4 had seven stars, and research question 5 had six stars total. Research questions noted with an asterisk (*) after them indicate a high level of consensus among stakeholders (i.e., four or more stakeholders assigned at least one vote to this question).

1. Among individuals who are not responding to usual asthma care, what is the effectiveness or comparative effectiveness of breathing techniques in the treatment of asthma?*
2. What is the effectiveness or comparative effectiveness of breathing techniques among individuals with anxiety and/or panic disorders (with and without asthma)?*
3. What is the effectiveness of multicomponent asthma interventions (i.e., incorporating breathing techniques, relaxation techniques, and other lifestyle modifications) on asthma outcomes?*
4. What is the effectiveness or comparative effectiveness of breathing techniques in the treatment of asthma among children and adolescents, and specifically adolescent females?
5. What is the effectiveness or comparative effectiveness of breathing techniques among individuals with varying levels of asthma severity and which individuals (i.e., those with mild, moderate, or severe asthma) benefit the most from using breathing techniques to help manage their asthma?*

### Literature Search Results

Our literature searches yielded 126 unique citations. After title and abstract review, we identified 15 studies that could potentially address one or more of the five high-priority research questions. All ongoing and recently published studies that were deemed to be relevant to one or more five high-priority research questions are provided in Appendix F. Funding opportunities that are potentially relevant to one or more high-priority future research needs questions are presented in Appendix G.

### Research Design Considerations

The appropriateness of a specific study design for a particular research topic depends on a number of factors, including how much is already known about the topic, the specific aims of the study, and other contextual factors regarding the populations, interventions, and outcomes of interest. Research areas with limited evidence bases and those considered to be at the hypothesis generating stage may be suitable for exploratory studies, including qualitative and observational designs, whereas areas with established theories and/or application may be more appropriate for experimental designs.

As was previously mentioned, six overarching future research needs emerged from our original CER that the stakeholders confirmed to be perhaps the most important, and obvious, needs in this topic area. Many of these needs related to issues of study design (e.g., studies among specific population subgroups and replication of previous studies/interventions) and emerged as part of specific research questions in the high priority list. Targeting specific subpopulations such as those who are experiencing ongoing asthma symptoms despite usual care (RQ1), those with comorbid panic and/or anxiety conditions (RQ2), children and adolescents (RQ4), and those with varying levels of asthma severity (RQ5) should be considered in future research designs. Additionally, it was noted that all study designs should account for the need for larger sample sizes (allowing for stratification by important population subgroups), and to both collect and report standard intervention details and outcomes.

Given the lack of trials in the original CER with direct comparisons of specific breathing techniques or other comparable interventions (e.g., other lifestyle modifications, asthma education, and changes to medication regimens), such designs are warranted. There is also a need to replicate the RCTs that test breathing technique interventions that most closely mirror “real world” interventions, for example the comparative effectiveness trial by Cowie and colleagues that evaluated the effects of the Buteyko breathing technique versus breathing physical therapy on asthma symptoms, controller medication use, quality of life, and pulmonary function.9

All of the highly-prioritized future research questions would ideally be addressed by conducting good-quality comparative effectiveness or effectiveness RCTs. Randomized controlled trials (RCTs), however, are often not the most practical option given the complexities involved and the resources required. In particular, many of the research questions may require large samples because of the small treatment effects expected for several outcomes. The feasibility of conducting RCTs may be also an issue, specifically in finding a sufficiently large population of individuals with specific characteristics (e.g., patients not responding to usual care [RQ1] or adolescent females [RQ4]) willing to comply with the intervention components for the duration of the intervention. Additionally, several of the breathing retraining interventions and other lifestyle interventions encourage patients to reduce or delay long-acting and quick-relief medications; future studies will require adequate justification and procedures for ensuring appropriate management of asthma symptoms.

For all of the high-priority research questions it is nearly impossible to have double-blind trials (i.e., where both participants and investigators are blind to the allocated treatment group) given that the intervention(s) being evaluated involve physical/lifestyle changes except for the case of sham interventions or direct comparisons of one breathing technique versus another. In this case, it is difficult to tell whether subjective outcomes such as self-reported quality of life or asthma symptoms are due to the actual interventions, to the extra attention participants receive, or merely to their belief that the intervention will help (a noted limitation in the original CER).

At least one of the research questions (RQ3) could be addressed within a two-by-two factorial design, in which participants are first randomized to an intervention focusing on one specific breathing technique, and then within each treatment group there is further randomization to evaluate a second question such as the effect of relaxation techniques. The principle advantage of a factorial design is the ability to answer two or more questions in a single trial for only a marginal increase in resources. The use of a two-by-two factorial design allows for the assessment of an interaction; typically testing ales mature hypothesis together with a more mature question with more reliable evidence While the fact that a possible interaction might affect the magnitude of the effect might be seen as a limitation, in this case it could be seen as a strength when we are trying to understand if such an interaction exists. However, disadvantages of this design include the potential for poor compliance or losses to followup given the additional intervention and more complicated trial operations in general.

In lieu of experimental designs or systematic reviews, prospective cohort studies could be considered. Given that the exposure in question (breathing techniques with or without other intervention components), appears to be a relatively rare adjunctive strategy to usual asthma care, however, it is unclear how feasible such a design would be. In addition, one of the issues expressed by several stakeholders and alluded to in the CER is that there is really no “standard” breathing technique intervention or therapy. Even within one specific category of breathing techniques (e.g., hyperventilation reduction), the specific interventions themselves (e.g., Buteyko vs. Papworth) and the components vary widely. Ideally, a prospective study with participant recruitment, data collection and analysis would be designed and carried out that is specifically intended to address the question(s) of interest. Limitations of prospective cohort studies, however, include the strong potential for confounding and again, the feasibility of finding a sufficient number of individuals practicing or willing to practice breathing retraining as an adjunctive treatment to manage their asthma for an ongoing period of time, and the risk of selection bias.

As more guidance becomes available regarding the minimal or standard components that should be including in the specific breathing interventions such as the Buteyko breathing technique, observational designs may become more appropriate. In fact, under the auspices of the Buteyko Breathing Educators Association, such standardization is underway. Establishing a registry of participants and/or conducting a prospective study designed to track patients receiving this standardized intervention (matched with equivalent controls) could allow for robust analysis of patient subgroups and multiple outcomes over time. While a retrospective cohort study would be appropriate for a number of the high-priority research questions, we feel that it is highly unlikely that there is any existing observational data available that captures the exposures of interest (e.g., the use of breathing techniques or other related interventions), outcomes of interest (e.g., asthma symptoms, quality-of-life), for the specific populations of interest (e.g., children, those with panic/anxiety disorders).

## Modified Analytic Framework

Using Figure 1 from our original CER as starting point, we developed a modified framework linking the identified future research needs to specific elements of the population, intervention, outcomes, and overarching questions (Figure 4).

Figure 4 Modified analytic framework incorporating identified future research needs

* Addressing these research questions would have been included in the original CER, thus, these indicate an evidence gap identified from the CER

Abbreviations: FEV_1_: forced expiratory volume in 1 second; FVC: forced vital capacity; MV: minute volume; PEF: peak expiratory flow; RQ: research question

Figure 4 depicts the oriiginal analytic framework of the original comparative effectiveness review by O'Connor and colleagues linking linking the five identified future research needs to specific elements of the population and intervention. Four research questions apply to the population: individuals not responding to usual care, those with anxiety and/or panic disorders, children/adolescents, and those with varying levels of asthma severity. The fifth research question applies to the intervention (use of multi-component asthma interventions including breathing techniques).