# References

1 American Lung Association - Epidemiology and Statistics Unit Research and Program Services Division. Trends in Asthma Morbidity and Mortality. Washinton, DC. American Lung Association. 2009. PMID: None.
2 Zahran HS, Bailey C, Garbe P. Vital signs: asthma prevalence, disease characteristics, and self-management education - United States, 2001-2009. MMWR Morb Mortal Wkly Rep. 2011;60(17):547-52. PMID: None. [pmid: 21544044].
3 Shaw A, Thompson EA, Sharp D. Complementary therapy use by patients and parents of children with asthma and the implications for NHS care: a qualitative study. BMC Health Serv Res. 2006;6:76. [pmid: 16776833].
4 Partridge MR, Dockrell M, Smith NM. The use of complementary medicines by those with asthma. Respir Med. Apr. 2003;97(4):436-8. [pmid: 12693806].
5 O'Connor E, Patnode CO, Burda BU, et al. Comparative effectiveness of breathing exercises and/or retraining techinques for the treatment of asthma. AHRQ Publication No. 12-EHC092-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2012. PMID: None.
6 Whitlock EP, Lopez SA, Chang S, et al. AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):491-501. [pmid: 19540721].
7 Brasure M, Shamliyan T, Butler M, et al. Finding evidence on ongoing studies. Future Research Needs Report No. 1. AHRQ Publication No. 11-EHC018-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2010. [pmid: 21433334].
8 Carey T, Sanders GD, Viswanathan M, et al. Framework for considering study designs for future research needs. AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2012. PMID: None.
9 Cowie RL, Conley DP, Underwood MF, et al. A randomised controlled trial of the Buteyko technique as an adjunct to conventional management of asthma. Respir Med. May. 2008;102(5):726-32. [pmid: 18249107].