# Executive Summary

## Background

An estimated 8.2 percent of the United States population has asthma including 9.6 percent of children and 7.7 percent of adults.1,2 Alternative and complementary treatment methods such as breathing retraining techniques have been advocated for the control of asthma given the range of asthma severity and concerns about long-term medication use. Specific breathing retraining approaches include those related to hyperventilation reduction (e.g., the Buteyko and Papworth methods) or nonhyperventilation-targeted methods (e.g., yoga breathing techniques, other physical therapy methods, biofeedback, and inspiratory muscle training [IMT]). These methods are assumed to be adjunctive to guideline-based care, with the primary goals of improving asthma control and reducing the use of medication.

In 2010, the Agency for Healthcare Research and Quality commissioned the Oregon Evidence-based Practice Center to conduct a comparative effectiveness review (CER) on the effectiveness of breathing exercises and/or retraining in the treatment of asthma.3 In this review, we addressed the following Key Questions:

1. Does the use of breathing exercises and/or retraining techniques improve health outcomes, including: symptoms (e.g., cough, wheezing, dyspnea); health-related quality of life (general and/or asthma-specific); acute asthma exacerbations; reduced use of quick-relief medications or reduced use of long-term control medications, when compared with usual care and/or other breathing techniques alone or in combination with other intervention strategies?
2. Does the use of breathing exercises and/or retraining techniques improve pulmonary function or other similar intermediate outcomes when compared with usual care and/or other breathing techniques alone or in combination with other intervention strategies?
3. What is the nature and frequency of serious adverse effects of treatment with breathing exercises and/or retraining techniques, including increased frequency of acute asthma exacerbations?

Our review sought to include studies that addressed the use of breathing techniques in adults and children 5 years of age and older with asthma and explored whether the effectiveness differed between different population subgroups (e.g., males/females; various types and severities of asthma; and/or different coexisting conditions). Additionally, we evaluated whether the effectiveness of these interventions varied by differences in intervention implementation or components.

The review identified 22 studies published between 1990 and December 2011 that examined the effectiveness or comparative effectiveness of breathing techniques on intermediate and/or health outcomes.3 In general, the evidence was low-to-moderate or insufficient to address the Key Questions adequately as it was based primarily on small, methodologically limited trials of heterogeneous populations with short followup and inconsistent outcome reporting.

The objective of this Future Research Needs project was to engage a diverse set of stakeholders to confirm, provide more detail, and prioritize the research needs that we identified in the CER. We also sought to provide information on ongoing studies of relevance to the prioritized list of research questions and study design considerations for the highly prioritized questions.

## Methods

To meet our objectives, we identified and recruited stakeholders, identified and revised the list of evidence needs articulated in the original CER, developed and administered a web-based prioritization questionnaire, and identified ongoing research, funding opportunities, and potential study designs for the high-priority future research needs (Figure A).

Figure A Future Research Needs process

Abbreviations: CER: comparative effectiveness review

Figure A is the Future Research Needs process. We identified and recruited 12 stakeholders at the same time that we identified evidence gaps and methods-related issues from the original comparative effectiveness review (CER) by O'Connor and colleagues. We conducted one-on-one interviews with six stakeholders who accepted our invitation to participate. They helped us confirm the list of important methods-related issues, revise the list of research gaps within the scope of the original CER and identifiy reseach gaps outside the scope of the original CER; all were confirmed by five of the six stakeholders. We reframed the evidence gaps as research questions and developed an online prioritization questionnaire and identified and recruited an additional 10 stakeholders to participate in the prioritization activity. Six stakeholders completed the online prioritization quesionnaire and identified five high-priority research questions from the list of 37 that were within the scope of the original CER. We conducted comprehensive literature searches to identify any ongoing studies that may answer these high-priority research questions, as well as potential funding opportunities to support future projects. We also developed a list of potential study designs to consider when developing a research protocol or funding opportunity that would answer these five research questions.

A total of 22 stakeholders were invited to participate in this project including patient advocates, researchers, research funders, providers/practitioners, and policymakers. We aimed to include individuals from both the respiratory and complementary and alternative medicine fields given the topic.

After developing a preliminary list of evidence gaps based on the CER and discussions with the lead author of the CER, we conducted one-on-one interviews with six stakeholders. We asked stakeholders to comment on whether or not they felt that the list of evidence needs was comprehensive and if there were better ways to express any of the research topics. We also asked if there were specific questions or topics that seemed out of place or did not belong on the list in terms of their importance to the field. Based on input from the one-on-one interviews, we revised the original list of research needs, reframed them as research questions, and organized them according to the specific population, intervention, comparator, or outcome (PICO) they addressed. We also listed methodological issues that were identified in the original CER or through our discussions.

Once the stakeholders had an opportunity to review the revised list of research needs we developed a web-based prioritization questionnaire that listed 37 research questions organized according to the PICO element most relevant to the question. The 37 research questions reflected questions that were considered both within and not within the scope of the original CER. The questionnaire used a forced prioritization exercise where each stakeholder had a limited number of votes to assign amongst the 37 questions. Respondents were asked to consider the potential impact, information gap, variation in research or clinical care, and uncertainty related to each research question in casting their votes. Based on the distribution of votes, questions that received a total of six or more votes (out of a possible 30) were considered high priority, those with four to five votes were considered medium priority, and those with zero to three votes were considered low priority.

Next, we searched for ongoing studies and funding opportunities that were relevant to the high-priority needs. We replicated the original CER literature search in 16 databases and searched for current funding opportunities posted by the National Institutes of Health and organizations specific to the topic. Finally, we evaluated potential study designs to address each of the highest-ranked research questions.

## Results

We enlisted a total of eight stakeholders in the identification and/or prioritization of research needs related to the use of breathing techniques in the treatment of asthma. Four individuals took part in both the identification and prioritization of research questions, two individuals only participated in helping to identify and refine evidence needs, and two individuals only participated in the prioritization of research questions.

A total of 37 specific research questions and six overarching methods-related research needs emerged after reviewing the original CER and consulting with the stakeholders. The six overarching issues were not included in the prioritization questionnaire, but were noted as extremely important issues in this area of research by all stakeholders. These issues were:

1. Trials of head-to-head comparisons of specific breathing techniques (matched for intensity), other lifestyle modifications, or medication regimens;
2. Studies with larger sample sizes, including multicenter trials;
3. Studies among specific population subgroups (e.g., non-White, children, older adults, individuals diagnosed with exercise-induced asthma) or heterogeneous trials with outcomes presented by subgroups;
4. Replication of or long-term followup of previous studies with positive effects or that use a standard breathing technique to further establish effectiveness;
5. Standardized intervention details reporting, including: specific breathing technique(s) practiced (e.g., shallow versus deep breathing, length of breath hold, nasal versus mouth breathing); and
6. Standardized outcomes reporting, including: asthma symptoms (e.g., wheezing, severity of asthma); pulmonary function (e.g., breathing rate, airway inflammation, daily PEF and PFV); cardiovascular outcomes (e.g., heart rate); quality of life (e.g., stress, anxiety); medication use; harms; psychosocial measures (e.g., self-efficacy)

Of the 37 research questions, 16 were considered to be within the scope of the original CER while 21 were considered to be out-of-scope of the original CER. Based on the prioritization questionnaire, we organized all of the within-scope future research needs questions into three categories: high-priority research questions (n=5), medium-priority research questions (n=3), and low-priority research questions (n=8). Four out of the five highly prioritized questions also received a high-level of consensus among stakeholders (i.e., more than half of the stakeholders allocated at least one vote to these questions). These four questions are indicated with an asterisk (*). Table A lists the final set of high-priority research questions and the number of total votes for each question.

Table A High-priority research questions

Research Question | Number of Votes
1. Among individuals who are not responding to usual asthma care, what is the effectiveness or comparative effectiveness of breathing techniques in the treatment of asthma?* | 8
2. What is the effectiveness or comparative effectiveness of breathing techniques among individuals with anxiety and/or panic disorders (with and without asthma)?* | 8
3. What is the effectiveness of multicomponent asthma interventions (i.e., incorporating breathing techniques, relaxation techniques, and other lifestyle modifications) on asthma outcomes?* | 8
4. What is the effectiveness or comparative effectiveness of breathing techniques in the treatment of asthma among children and adolescents, and specifically adolescent females? | 7
5. What is the effectiveness or comparative effectiveness of breathing techniques among individuals with varying levels of asthma severity and which individuals (i.e., those with mild, moderate, or severe asthma) benefit the most from using breathing techniques to help manage their asthma?* | 6

Using original CER analytic framework as starting point, we developed a modified framework linking the high-priority future research needs to specific elements of the population, intervention, outcomes, and overarching questions (Figure B).

Figure B Modified analytic framework incorporating identified future research needs

* Addressing these research questions would have been included in the original CER, thus, these indicate an evidence gap identified from the CER

Abbreviations: FEV1: forced expiratory volume in 1 second; FVC: forced vital capacity; MV: minute volume; PEF: peak expiratory flow; RQ: research question

Figure B depicts the oriiginal analytic framework of the original comparative effectiveness review by O'Connor and colleagues linking linking the five identified future research needs to specific elements of the population and intervention. Four research questions apply to the population: individuals not responding to usual care, those with anxiety and/or panic disorders, children/adolescents, and those with varying levels of asthma severity. The fifth research question applies to the intervention (use of multi-component asthma interventions including breathing techniques)

Our literature search for relevant evidence yielded 126 unique citations. After title and abstract review, we identified 15 studies that could potentially address one or more of the research questions. We identified funding opportunities from 8 different organizations that are potentially relevant to one or more of the high-priority future research needs questions.

The appropriateness of a specific study design for a particular research topic depends on a number of factors, including how much is already known about the topic, the specific aims of the study, and other contextual factors regarding the populations, interventions, and outcomes of interest. As was previously mentioned, six overarching future research needs emerged from our original CER that the stakeholders confirmed to be perhaps the most important, and obvious, needs in this topic area. Many of these needs related to issues of study design (e.g., studies among specific population subgroups and replication of previous studies/interventions) and emerged as part of specific research questions in the high priority list. Targeting specific subpopulations such as those who are experiencing ongoing asthma symptoms despite usual care (RQ1), those with comorbid panic and/or anxiety conditions (RQ2), children and adolescents (RQ4), and those with varying levels of asthma severity (RQ5) should be considered in future research designs. Additionally, it was noted that all study designs should account for the need for larger sample sizes (allowing for stratification by important population subgroups), and to both collect and report standard intervention details and outcomes. Given the lack of trials in the original CER with direct comparisons of specific breathing techniques or other comparable interventions (e.g., other lifestyle modifications, asthma education, and changes to medication regimens), such designs are warranted. There is also a need to replicate the RCTs that test breathing technique interventions that most closely mirror “real world” interventions.

## Discussion

The purpose of this project was to engage a diverse set of stakeholders to identify and prioritize future research needs related to the use of breathing techniques in the management of asthma. Our findings suggested that future research in the area of the use of breathing techniques and retraining interventions for asthma management should focus on: the effectiveness of breathing retraining on asthma in [underlined: specific subpopulations] and the effectiveness of [underlined: multicomponent interventions] that include breathing techniques. Four out of the five high-priority questions related to understanding the effectiveness or comparative effectiveness of breathing techniques in specific groups including children and adolescents, those not responding to usual asthma care, those with asthma of varying severities, and those also experiencing panic or anxiety disorders.

Our process of engaging stakeholders and reviewing recent literature highlighted the fact that there continues to be limited research in this area in general. The most important research contributions in this field might relate to replicating the good quality studies included in our original CER and including standardized measurement and reporting, including details about the intervention itself. Well-designed randomized controlled trials would produce the most valid and generalizable results, if the studies' inclusion and exclusion criteria and setting reflect the context of real-world asthma care. However, such trials would need large sample sizes in order to account for presumably small-to-modest effect sizes. Prospective or retrospective cohort studies typically require fewer resources in terms of effort and funds to recruit a sufficient sample and execute the study. However, given that the exposure in question (breathing techniques with or without other intervention components) appears to be a relatively rare adjunctive strategy to usual asthma care, it is unclear how feasible such a design would be.

The list of prioritized research needs did not deviate considerably from the list of evidence gaps and future research needs articulated in our original CER. However, the engagement of diverse stakeholders helped to add more contextual details to these needs and helped articulate broader issues related to this topic area. The full list of 37 research questions and five highly-prioritized questions, lists of ongoing studies and potential funding opportunities, and research design considerations provide a basis for investigator-initiated research and related funding opportunities.

## References

1 American Lung Association - Epidemiology and Statistics Unit Research and Program Services Division. Trends in Asthma Morbidity and Mortality. Washington, DC. American Lung Association. 2009.
2 Zahran HS, Bailey C, Garbe P. Vital signs: asthma prevalence, disease characteristics, and self-management education - United States, 2001-2009. MMWR Morb Mortal Wkly Rep. 2011;60(17):547-52. [pmid: 21544044].
3 O'Connor E, Patnode CO, Burda BU, et al. Comparative effectiveness of breathing exercises and/or retraining techniques for the treatment of asthma. AHRQ Publication No. 12-EHC092-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2012.