# Stakeholders

Although the target audience for a future research needs document is the research community and/or funders of research, other stakeholders have an important role in providing input into the future research agenda. Stakeholders include patients and caregivers, practicing clinicians, relevant professional and consumer organizations, researchers, purchasers of health care, and others with experience in making health care decisions. They are selected to provide broad expertise and perspectives specific to the topic, and input on types of information helpful in healthcare decision-making. The EPC solicits input from stakeholders when identifying high priority research gaps and needed new research. Stakeholders are not involved in analyzing the evidence or writing the report and have not reviewed the report, except as given the opportunity to do so through the public review mechanism.

Stakeholders must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals are invited to serve as stakeholders and those who present with potential conflicts may be retained. The TOO and the EPC work to balance, and manage any potential conflicts of interest identified.

- Rebekah Buckley, M.P.H, C.R.T., A.E.-C. *
  * Participated in identification of evidence gaps only
  Centers for Disease Control
  Atlanta, GA
- Sussanna Czeranko, N.D.
  National College of Natural Medicine
  Portland, OR
- Cheryl De Pinto, M.D. †
  † Participated in prioritization of evidence gaps only (i.e., online prioritization questionnaire)
  Center for Maternal and Child Health
  Department of Health and Mental Hygiene
  Baltimore, MD
- Benjamin Kligler, M.D.
  Beth Israel Medical Center
  New York City, NY
- Paul Lehrer, Ph.D. *
  Robert Wood Johnson University Hospital
  New Brunswick, NJ
- Alicia Meuret, Ph.D. †
  Southern Methodist University
  Dallas, TX
- Natalie Napolitano, M.P.H., R.R.T.-N.P.S., A.E.-C.
  American Association of Respiratory Care
  Irving, TX
- Robert Zeiger, M.D.
  Childhood Asthma Research Education
  Network (CARE), Kaiser Permanente
  San Diego, CA