# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Elizabeth O'Connor, Ph.D., Daphne Plaut, M.L.S. and C. Samuel Peterson.