# Discussion

The purpose of this project was to engage a diverse set of stakeholders to identify and prioritize future research needs related to the use of breathing techniques in the management of asthma. Our recent CER included an initial list of evidence gaps and future research needs from which this process drew from.5 We also aimed to provide relevant information regarding ongoing studies and research design considerations for the highly-prioritized topics. Our findings suggested that future research in the area of the use of breathing techniques and retraining interventions for asthma management should focus on the effectiveness of breathing retraining on asthma in [underlined: specific subpopulations] and the effectiveness of [underlined: multicomponent interventions] that include breathing techniques. Four out of the five high-priority questions related understanding the effectiveness or comparative effectiveness of breathing techniques in specific groups including children and adolescents, those not responding to usual asthma care, those with asthma of varying severities, and those also experiencing panic or anxiety disorders.

Our process of engaging stakeholders and reviewing recent literature highlighted the fact that there continues to be limited research in this area in general. The most important research contributions in this field might relate to replicating the good quality studies included in our original CER and including standardized measurement and reporting, including details about the intervention itself. The list of prioritized research needs did not deviate considerably from the list of evidence gaps and future research needs articulated in our original CER. The engagement of diverse stakeholders, however, helped to add more contextual details to these needs and helped articulate broader issues related to this topic area.

Although not within the scope of our original review, a common theme throughout the stakeholder discussions and in several of the future research needs related to the mechanisms or pathophysiology by which breathing techniques might affect asthma outcomes. Several stakeholders expressed the need for more research related to the effects of breathing techniques on the autonomic system, including needing a better understanding of the role that general relaxation and reduced anxiety played in affecting asthma symptoms.

For questions that were out-of-scope for the original CER (e.g., cost-effectiveness of breathing technique interventions or questions that address the effectiveness of breathing techniques on other outcomes such as sleep apnea) it may be appropriate to consider a systematic review to identify if trials or observational studies have already been conducted to answer these questions. We suspect, however, that there is minimal data of fair or good quality that address many of these other areas given the paucity of data we found related to the Key Questions from the original CER. Given a sufficient number and quality of existing research, however, some questions may be addressable through narrative review or meta-analysis. If we were to broaden the inclusion/exclusion criteria from the original CER, we may find relevant data to abstract that pertains specifically to the future research needs identified here. For instance, we did not include any studies that were limited to individuals with anxiety or panic disorder without asthma (RQ2) in the original CER. Expanding our search strategy and inclusion criteria to include these studies might allow for more data to include in a systematic review.

There are a number of limitations to this future research needs project worth noting. First, this area of research – the use of breathing techniques and even complementary and alternative therapies more broadly, in asthma management—is relatively small and specialized. There is a paucity of research in this area, as seen in our CER, which included only 22 studies of low applicability to health care in the United States addressing four types of breathing techniques: hyperventilation reduction, yoga breathing, IMT and other nonhyperventilation reduction methods. Also, throughout the original CER and FRN processes, we discovered that there are a very small number of individuals and organizations conducting research in this area. While there are likely thousands of practitioners—respiratory therapists, physical therapists/physiotherapists, and Buteyko educators—with practical expertise in this area, identifying such individuals with a keen knowledge of the research needs was difficult. While several of the potential stakeholders we identified were considered experts in the area of asthma management or complementary and alternative medicine, most of them declined from participating given their lack of knowledge regarding the use of breathing techniques specifically. Half of the stakeholders who agreed to participate were the principal investigator or a co-investigator of studies included in our CER. While their involvement provided rich detail and highly applicable considerations, their participation may have biased the development of the research gaps and the final prioritized list in favor of their future research plans. The involvement of other stakeholders, however, should have reduced this bias. Likewise, we identified very few funding opportunities specific to research in breathing techniques; most opportunities broadly addressed asthma in general which may limit the possibility of addressing the high-priority research questions identified in this FRN project.

Second, we did not search for or provide a list of ongoing studies for the full list of research questions before we provided the stakeholders the opportunity to review and prioritize the questions, as is recommended.7 Providing this information to the stakeholders while they were prioritizing questions may have resulted in a different set of priorities if they felt that the topic was already being covered in current research or alternatively, if a lack of research on one particular subject was identified. In our review of the ongoing and recently completed research, however, we only identified 15 studies that may apply to one or more of the high-priority questions. We suspect that the yield would have been similar for all 37 questions and expect that the stakeholders' awareness of these studies would have not changed the results if presented to them before to the prioritization activity.

Finally, we did not engage the stakeholders in qualitative discussions specifically about the high-priority research questions. Our original interviews helped shape the final list of questions listed on the prioritization questionnaire, yet, did not provide specific detail on any particular question. Such discussions may have yielded more depth regarding the specific populations, interventions, comparators, outcomes and even the ideal study designs that should be used when answering the research questions.

Despite these limitations, we successfully identified and engaged a diverse group of stakeholders to help further elucidate research needs in this specialized field. The full list of 37 research questions and five highly-prioritized questions within the scope of the original CER, lists of ongoing studies and potential funding opportunities, and research design considerations provide a basis for investigator-initiated research and related funding requests.