# Background

## Context

An estimated 8.2 percent of the United States population has asthma including 9.6 percent of children and 7.7 percent of adults.1,2 In general, long-term control and quick relief medications are used to control asthma by reducing airway inflammation and resolving acute exacerbations, respectively. These medications, although highly effective, are not without potential risks. Individuals with asthma are concerned about the use of asthma medications and are interested in alternative treatment methods to minimize symptoms related to their asthma and potentially reduce medication use.3,4

Alternative and complementary treatment methods such as breathing retraining techniques have been advocated for the control of asthma given the range of severity and causes in addition to the concerns about long-term medication use. Specific breathing retraining approaches include those related to hyperventilation reduction (e.g., the Buteyko and Papworth methods) or nonhyperventilation-targeted methods (e.g., yoga breathing techniques, other physical therapy methods, biofeedback, and inspiratory muscle training [IMT]). These methods are assumed to be adjunctive to guideline-based care, with the primary goals of improving asthma control and reducing the use of medication.

In 2010, the Agency for Healthcare Research and Quality (AHRQ) commissioned the Oregon Evidence-based Practice Center (EPC) to conduct a comparative effectiveness review (CER) on the effectiveness of breathing exercises and/or retraining in the treatment of asthma.5 The Key Questions addressed by the review were:

1. In adults and children 5 years of age and older with asthma, does the use of breathing exercises and/or retraining techniques^*^ improve health outcomes, including: symptoms (e.g., cough, wheezing, dyspnea); health-related quality of life (general and/or asthma-specific); acute asthma exacerbations; reduced use of quick-relief medications or reduced use of long-term control medications, when compared with usual care and/or other breathing techniques alone or in combination with other intervention strategies?
  * For example: the Buteyko breathing technique; inspiratory muscle training; breathing physical therapy including paced and pursed lip breathing exercises; the Papworth method; biofeedback- and technology-assisted breathing retraining; and yoga breathing exercises.
  a. Does the efficacy and/or effectiveness of breathing techniques for asthma health outcomes differ between different subgroups (e.g., adults/children; males/females; different races or ethnicities; smokers/nonsmokers; various types and severities of asthma; and/or different coexisting conditions)?
  b. Does the efficacy and/or effectiveness of breathing techniques for asthma health outcomes differ according to variations in implementation (e.g., trainer experience) and/or nonbreathing components of the intervention (e.g., anxiety management)?
2. In adults and children 5 years of age and older with asthma, does the use of breathing exercises and/or retraining techniques improve pulmonary function or other similar intermediate outcomes when compared with usual care and/or other breathing techniques alone or in combination with other intervention strategies?
  a. Does the efficacy and/or effectiveness of breathing techniques for other asthma outcomes differ between different subgroups (e.g., adults/children; males/females; different races or ethnicities; smokers/nonsmokers; various types and severities of asthma; and/or different coexisting conditions)?
  b. Does the efficacy and/or effectiveness of breathing techniques for other asthma outcomes differ according to variations in implementation (e.g., trainer experience) and/or nonbreathing components of the intervention (e.g., anxiety management)?
3. What is the nature and frequency of serious adverse effects of treatment with breathing exercises and/or retraining techniques, including increased frequency of acute asthma exacerbations?
  a. Do the safety or adverse effects of treatment with breathing techniques differ between different subgroups (e.g., adults/children; males/females; different races or ethnicities; smokers/nonsmokers; various types and severities of asthma; and/or different coexisting conditions)?

The analytic framework (Figure 1), with Key Questions incorporated, guided the review and outlined the target populations, interventions and outcomes.

Figure 1 Original analytic framework for the comparative effectiveness review5

Abbreviations: FEV_1_: forced expiratory volume in 1 second; FVC: forced vital capacity; MV: minute volume; PEF: peak expiratory flow

Figure 1 is an analytic framework that depicts the key questions of the original comparative effectiveness review by O'Connor and colleagues, “Breathing Exercises and/or Retraining Techniques in the Treatment of Asthma: Comparative Effectiveness”. In general, the figure illustrates how the use of breathing exercises or retraining techniques may result in improved intermediate outcomes such as forced expiratory volume or peak expiratory flow, and/or improved heath outcomes such as improved symptom severity and quality of life. The figure also depicts the possibility of adverse events occurring after treatment.

## Findings of the CER

The review identified 22 studies published between 1990 and December 2011 that examined four different categories of breathing techniques: hyperventilation reduction breathing techniques (e.g., Buteyko breathing), yoga breathing techniques, inspiratory muscle training (IMT), and other nonhyperventilation reduction breathing techniques.5 In general, the evidence was low-to-moderate or insufficient to address the Key Questions adequately as it was based primarily on small, methodologically limited trials of heterogeneous populations with short followup and inconsistent outcome reporting. There was moderate evidence that showed a reduction in asthma symptoms and reliever medication use with hyperventilation reduction breathing techniques interventions with five or more hours of direct instruction. There was also moderate evidence that hyperventilation reduction breathing techniques do not improve pulmonary function.5

The evidence was low or insufficient to show effects of hyperventilation reduction breathing techniques on medication use, quality of life, or functioning compared with controls. Compared to other breathing techniques, hyperventilation reduction was more likely to reduce reliever medication, but no more likely to improve asthma symptoms, medication use, quality of life, or pulmonary function, however, the evidence was low. Similarly, yoga breathing may improve asthma symptoms, quality of life and pulmonary function and quality of life but the strength of the evidence was low.5

There was insufficient evidence on the effect of yoga on asthma medication use and the effect of IMT and other nonhyperventilation reduction breathing techniques on asthma symptoms, medication use, quality of life or pulmonary function. There was no evidence of harms associated with the use of hyperventilation reduction breathing techniques, yoga breathing, IMT, and other nonhyperventilation reduction breathing techniques, although the evidence to support this was low. There was also insufficient evidence to determine whether individual patient characteristics (e.g., age, sex, etc.) or the provider's certification and/or training influenced the treatment effects or if the patient experienced any harms. Exploratory analyses suggested comprehensive approaches may be more likely to show a benefit than those that isolate a single aspect of breathing.5

## Objective

The objective of this Future Research Needs (FRN) project was to engage a diverse set of stakeholders to confirm, provide more detail, and prioritize the research needs that were identified in the CER. We also sought to provide information on ongoing studies of relevance to the prioritized list of research questions and study design considerations for the highly prioritized questions.