# Relevant Funding Opportunities

Organization | Web site | Details of selected funding opportunities
American Asthma Foundation Research Program | http://www.americanasthmafoundation.org/grants/ | - Senior Investigator Award $750,000 ($250,000 per year for three years) and Early Excellence Award $450,000 ($150,000 per year for 3 years). Eligible countries: United States, Australia, Canada, Ireland, Israel, Sweden and the United Kingdom. Review criteria:; ○ Innovation: cutting-edge research, new-to-the-field thinking; ○ Relevance to asthma: potential for new insights into causes and treatments; ○ Research proposal: importance and clarity; ○ Investigator: productivity and ingenuity
American Lung Association | http://www.lung.org/finding-cures/grant-opportunities/ | - Lung Health Dissertation Grant (one grant available): $21,000 per year. Pre-doctoral support for nurses or students with an academic career focused on the various disciplines of social science. Research areas of particular interest are: psychosocial, behavioral, health services, health policy, epidemiological, biostatistical and educational matters related to lung disease.; - Senior Research Training Fellowship (8-10 grants available): $32,500 per year. Post-doctoral support for MDs and/or PhDs receiving further academic training as scientific investigators. Research areas of particular interest are: adult pulmonary medicine, pediatric pulmonary medicine and lung biology.; - Clinical Patient Care Research Grant (1-2 grants available): $40,000 per year. Provides seed monies for junior investigators working on traditional clinical studies examining methods of improving patient care and/or treatment for lung disease.; - Social-Behavioral Research Grant: (1-2 grants available): $40,000 per year. Provides seed monies for junior investigators working on epidemiological and behavioral studies examining risk factors affecting lung health. This grant includes studies concerning the ethical, legal and economic aspects of health services and policies.; - American Lung Association / The CHEST Foundation Asthma Clinical Patient Care Grant: (one grant available): $40,000 per year. Provides seed monies for junior investigators working on traditional clinical studies examining methods for improving patient care and treatment for asthma.
Asthma UK | http://www.asthma.org.uk/how-we-help/groundbreaking-research/for-researchers/apply-for-funding/ | - Project Grants: Every two years from 2013, we will invite applications for larger, longer duration grants to tackle challenges in stable research fields and research fields in flux aligned with our priority research areas.; - Innovation Grants: In alternate years from 2014, we will offer small grants to explore original ideas in inherently novel priority asthma research areas.; - Priority Needs Grants: Priority Needs Grants are the mechanism within Asthma UK's 2011 to 2016 Research Strategy which enables the charity to strategically commission projects in order to address or highlight important issues in asthma research and/or service delivery.
Australian Association of Asthma Foundations | http://www.asthmaaustralia.org.au/research/grants.php | - Grants in the Area of Asthma: These grants are investigator led projects relating to asthma and may be in basic sciences, clinical fields, epidemiology, public health etc. Grants will be awarded to applicants who best fulfill the grant selection criteria and who are employed at an institution with appropriate research facilities, under the supervision of a responsible investigator.
British Lung Foundation | http://www.lunguk.org/research/grants_available_how_to_apply | - Leeds Trust Project Grant 2012: The British Lung Foundation is offering a grant of £100,000 for research into ANY lung disease. Principal applicants can be based anywhere in the UK.; - Early Career Investigator Awards: One award of £800 is being offered by the British Lung Foundation. A runner-up prize of £200 will also be available. Both prizes are designed to help the careers of the most promising early-career investigators carrying out original research in respiratory medicine and respiratory science during the past year. A selection committee judges the awards based on abstracts presented at the British Thoracic Society Winter Meeting. More information can be found at the British Thoracic Society website.
Buteyko Breathing Educators Association | http://www.buteykoeducators.org/content.aspx?page_id=0&club_id&equals;174916 | No funding opportunities identified
Buteyko-USA | http://www.buteyko-usa.com/Default.htm | No funding opportunities identified
Buteyko Institute of Breathing and Health | http://www.buteyko.info/index.asp | No funding opportunities identified
Central Council for Research in Yoga and Naturopathy | http://www.ccryn.org/grant%20research.html | - Grant-in-Aid: Given to the premier Medical and Yoga and Naturopathy Institutes for conducting clinical research to establish efficacy of Yoga and Naturopathy in prevention and treatment of various diseases. Application available online (no further details).
Grants.gov | http://www.grants.gov | - Asthma in Older Adults (R03): Issued by the NHLBI and the NIAID encourages applications that propose to study the pathophysiology, epidemiology, diagnosis, and/or management of asthma in older adults.; - Obesity and Asthma: Awareness and Management (R01): Issued by the NINR to stimulate research to examine the interconnections of asthma and obesity including intervention studies targeting asthma or obesity and their effects on each one, and possible mechanisms of action are encouraged.
National Asthma Campaign | http://www.nationalasthmacampaign.org/home.asp | No funding opportunities identified
Royal College of General Practitioners | http://www.rcgp.org.uk/ | No funding opportunities identified

Abbreviations: NHLBI=National Heart, Lung and Blood Institute; NIAID=National Institute of Allergy and Infectious Disease; NINR=National Institute for Nursing Research