# Recently Published and Ongoing Studies of Relevance

1 Randomized trial of the effect of an integrative medicine approach to the management of asthma in adults on disease-related quality of life and pulmonary function. J Aust Tradit Med Soc. 2011;17:165-7.
2 LUCHAR - Latinos Using Counseling for Help With Asthma and Anxiety Reduction. New York, NY. Yeshiva University. 2012. http://clinicaltrials.gov/ct2/show/NCT01583296. June 7, 2012.
3 The effectiveness of a comprehensive lifestyle modification programme for asthma patients (ETHICO study): a randomized controlled trial. Hradec Kralove Charles University. 2012. www.drks.de/DRKS00003535. June 7, 2012.
4 Ahmad R. Breathing and mild physical exercise therapy for asthma. Kuwait. Dasman Diabetes Institute. 2012. http://clinicaltrials.gov/ct2/show/NCT01509443. June 7, 2012.
5 Ashfaque K, Bhat MR. A clinical study on effect of breathing exercises on bronchial asthma: a controlled trial. Biomedicine. 2012;32(1):96-100.
6 Balk J. Yoga and preak flow rates in pregnant asthmatics. Pittsburgh, PA. Magee Women's Institute and Foundation. 2002. http://projectreporter.nih.gov/project_info_details.cfm?icde=0&projectnumber&equals;6K08AT000782-05. June 7, 2012.
7 Ball A. Breath controlled computer game controller for asthma therapy. Somerville, MA. Abid, Inc. 2010. http://projectreporter.nih.gov/project_info_description.cfm?aid=7928445&icde&equals;12977959&ddparam&equals;&ddvalue&equals;&ddsub&equals;&cr&equals;1&csb&equals;default&cs&equals;ASC. June 7, 2012.
8 Feldman J. Adaptation of a behavioral treatment for Latinos with panic disorder and asthma. New York, NY. Yeshiva University. 2012. http://projectreporter.nih.gov/project_info_description.cfm?aid=8197939&icde&equals;12977992&ddparam&equals;&ddvalue&equals;&ddsub&equals;&cr&equals;1&csb&equals;default&cs&equals;ASC. June 7, 2012.
9 Jeter AM, Kim HC, Simon E, et al. Hypoventilation training for asthma: a case illustration. Appl Psychophysiol Biofeedback. Mar. 2012;37(1):63-72. [pmid: 22210521].
10 Lehrer PM. Respiratory sinus arrythmia biofeedback for asthma. Pistataway, NJ. University of Medicine and Dentisty of New Jersey, Robert Wood Johnson Medical School. 2002. http://projectreporter.nih.gov/project_info_details.cfm?aid=6596175&icde&equals;0. June 7, 2012.
11 Lehrer PM. Heart rate variability biofeedback: its role in asthma therapeutics. Pistataway, NJ. University of Medicine and Dentisty of New Jersey, Robert Wood Johnson Medical School. 2012. http://projectreporter.nih.gov/project_info_description.cfm?projectnumber=5R01HL089495-02. June 7, 2012.
12 Mekonnen D, Mossie A. Clinical effects of yoga on asthmatic patients: a preliminary clinical trial. Ethiop J Health Sci. Jul. 2010;20(2):107-12. [pmid: 22434968].
13 Pbert L. Asthma and mindfulness-based stress reduction (MBSR). Worcester, MA. University Massachusetts Medical School Worcester. 2007. http://clinicaltrials.gov/ct2/show/NCT00682669. June 7, 2012. PMID: None.
14 Thomas M, McKinley RK, Freeman E, et al. Breathing retraining for dysfunctional breathing in asthma: a randomised controlled trial. Thorax. 2001;56(Suppl 3):iii-17.
15 Yu MC, Chen JS, Chang KJ, et al. I-m-Breath: The effect of multimedia biofeedback on learning abdominal breath. Lect Notes Comp Sci. 2011;6523(Part 1):548-58.